# SUMMARY AND DISCUSSION

## SUMMARY OF FINDINGS AND STRENGTH OF EVIDENCE

We identified 70 papers (published from 1995 to 2015) representing 62 studies of 64 unique study populations (including 40 RCTs) and enrolling 34,457 patients. Fifty-two of the unique populations studied (81%) were adults with cardiovascular disease, diabetes, dyslipidemia, or hypertension; other conditions included depression, chronic kidney disease, chronic obstructive pulmonary disease, and polypharmacy. Seventeen studies were conducted, at least in part, at VA Medical Centers. Most pharmacist-led interventions were multifaceted, conducted in person, and included multiple contacts between pharmacists and patients. Most studies were not primarily designed to evaluate the effect of pharmacist-led care on clinical or resource use outcomes. Intermediate measures were the most frequently reported outcome with the most common (k=45) being target goal attainment for HbA1c, blood pressure, and cholesterol levels. We included a wide range of studies (randomized controlled trials, controlled trials, interrupted time series, and cohort studies) in order to evaluate a diverse body of literature related to system-level quality improvement projects and pharmacist-led care.

We rated strength of evidence for disease-specific clinical events (low strength of evidence that pharmacist-led care and usual care were similar), patient satisfaction (insufficient evidence), urgent care/emergency department visits and hospitalizations (moderate strength of evidence that pharmacist-led care and usual care were similar), non-adherence to medications (low strength of evidence that pharmacist-led care and usual care were similar), and goal attainment (moderate strength of evidence that pharmacist-led care increased the proportion of patients achieving glycemic, blood pressure, and cholesterol goals compared to usual care). While we did not formally assess strength of evidence on other outcomes we did find that pharmacist-led care was also similar to usual care for depression, health-related quality of life, all-cause mortality, and cost outcomes. However, due to differences in costs reported across studies (program costs, medication costs, visit costs), it is difficult to reach a conclusion about costs. Very few studies reported drug-related problems (inappropriate medication or dosage, drug interactions). Patients in the pharmacist-led care groups generally received a greater number or dose of medications though it was difficult to evaluate whether increased number or dose of medications was an indicator of better care quality.

We identified one additional study that attempted to address the gap in reporting of adverse events.81 In a post-hoc analysis, the authors achieved a larger sample size by pooling data from 2 similarly conducted RCTs comparing pharmacist-led interventions to usual care for patients with heart failure16 and hypertension. Adverse drug events and medication errors were secondary outcomes in the original trials. There were 75 events in the intervention groups and 135 events in the control groups. The risk ratio for all events (adverse drug events, preventable adverse drug events, potential adverse drug events, and medication errors) was 0.66 (95% CI 0.50, 0.88) favoring the intervention groups over the control groups. Risk ratios for the individual event categories were similar although not significant for preventable or potential adverse drug events.

Our results concur with findings from other recent systematic reviews. Viswanathan et al, in a review for the Agency for Healthcare Research and Quality (AHRQ), focused on MTM and required interventions to include at least 3 elements: comprehensive medication review, patient-directed education and counseling, and coordination of care.9 They found low strength of evidence for a benefit of MTM for health plan expenditures (based on 3 RCTs) although the evidence from non-randomized trials and cohort studies was rated as insufficient strength. There was also a benefit of MTM for hospitalization risk for diabetes (based on one cohort study) but not CHF or COPD (insufficient evidence). There were mixed results for number of hospitalizations with 3 RCTs finding no benefit and one cohort finding a benefit of MTM. Only 5 studies were included in both the AHRQ review and our review. However, both reviews found limited reporting of outcomes such as clinical events, mortality, adverse drug events, and drug-related problems. The authors of the AHRQ review also commented on difficulty interpreting findings as higher values for some outcomes (eg, office visits, medication use) may indicate better care for some patients and poorer care for others and many sources of variability are not accounted for in the data analyses.

Another review focused exclusively on blood pressure control in patients with or without diabetes.82 Included studies were RCTs with interventions delivered by a pharmacist alone or in collaboration with other healthcare professionals. In pooled analyses, pharmacist interventions were associated with reductions in systolic and diastolic blood pressure although heterogeneity was high (I^2^=67% for the systolic blood pressure analysis, I^2^=83% for the diastolic blood pressure analysis). Subgroup analyses by the type of pharmacist intervention showed greater changes in systolic and diastolic blood pressure with pharmacist-led care compared to collaborative care. No other outcomes were reported.

A 2010 review included studies of interventions, conducted in the US, where the pharmacist was involved in direct patient care (with a “discernable contribution”).83 Outcomes of interest were categorized as therapeutic (eg, blood pressure, hospitalizations, mortality, appropriate medication use, eye exams), safety (eg, adverse drug events, medication errors), or humanistic (eg, patient adherence, patient knowledge, quality of life). The authors reported the percentage of studies reporting an outcome with favorable, non-favorable, mixed, no effect, and unclear findings then performed meta-analyses with data from RCTs if more than 4 RCTs reported the outcome. The therapeutic outcomes eligible for meta-analysis were HbA1c, LDL, and blood pressure. Pooled standard mean difference data favored the pharmacist involvement. Data on adverse drug events (safety outcome) were pooled with an odds ratio favoring the pharmacist involvement (OR 0.53 [95% CI 0.33, 0.83]). Standard mean difference data could also be pooled for 6 humanistic outcomes. Significant differences favoring pharmacist involvement were noted for medication adherence, patient knowledge, and quality of life (general health). Non-significant findings were reported for patient satisfaction and 2 quality of life dimensions – physical functioning and mental health.

## APPLICABILITY

The chronic disease conditions addressed in the included studies (cardiovascular disease, chronic kidney disease, COPD, depression, diabetes mellitus, and hypertension) are common among Veterans. Seventeen studies were conducted in VA facilities. The model of pharmacist-led care reported in these studies varied but likely is similar to ongoing programs in VA.

## LIMITATIONS AND RESEARCH GAPS/FUTURE RESEARCH

Many of the outcomes reported in this review were not the study-defined primary endpoints and therefore not supported by rigorous research methods or statistical inferences. Among studies included in our review, sample sizes were too small and follow-up periods too short to detect differences in mortality. There was limited reporting of other clinical events, health-related quality of life, and patient satisfaction. When assessed, authors used varied methods for determining health-related quality of life and patient satisfaction. Scale scores were often not validated, of unknown clinical importance, or included selected findings from subscales. Interventions varied in composition, delivery mode, and intensity as did the usual care comparator, making it difficult to draw conclusions about important intervention characteristics.

One hypothetical benefit of pharmacist-led care for chronic diseases is increased access to care for patients. None of the included studies reported typical measures of access and only 4 studies (2 in patients with depression and one each in patients with hypertension or diabetes) reported patient satisfaction or patient perception measures related to access (eg, satisfaction with ability to reach someone in an emergency or satisfaction with availability of advice). Intervention-based increases in the number of scheduled visits or telephone calls may not represent improved access. Further research is needed with conventional measures of access.

A consistent definition of an office visits outcome is needed to distinguish regularly scheduled office visits, study-related office visits, and unplanned office visits. In many cases it was unclear whether the visit was with a pharmacist or primary care provider. Also, a consistently reported cost outcome that includes all of the important economic factors involved in pharmacist-led care would facilitate comparisons across studies and provide more accurate cost-effectiveness estimates.

There was limited reporting of important drug-related problems, in particular drug interactions and inappropriate medications and/or dosages. Some studies did report on adherence with mixed, inconclusive results. Despite existing definitions of polypharmacy, an isolated measure of the number of medications is not an indicator of quality of care as there are situations where adding medications and/or increasing dosages may be helpful. Similarly, de-prescribing medications that emerging evidence suggests are not beneficial and may provide harm may also be helpful. Further research is needed to define and describe these interventions and their association with patient outcomes and value

Finally, the demonstrated improvement in laboratory and physiologic goal attainment due to pharmacist-led care is potentially encouraging. Intervention group pharmacists successfully achieved the intended study objectives. The target goals were based, in part, on recommendations from selected existing clinical practice guidelines and performance measures. The results indicate that future pharmacist-led programs are likely to achieve intended goals. However, there is conflicting evidence that target goals for glycemic, blood pressure, or cholesterol control have long-term beneficial effects on patient outcomes including clinical events, satisfaction, access, hospitalizations, and costs. Therefore, future research needs to carefully assess whether the magnitude of effect on selected intermediate laboratory and physiologic goals translate to improved patient outcomes including clinical events, satisfaction, access, hospitalizations, and costs. Few studies reported differences in potential harms. Thus the available evidence does not answer the question about whether the benefits of pharmacy-led interventions justify potential harms and costs. Ideally, future studies will be designed to fully and accurately address final patient outcomes and cost effectiveness.

## CONCLUSIONS

Evidence is limited on the effectiveness and harms of pharmacist-led chronic disease management compared to usual care for clinical outcomes (ie, clinical events, all-cause mortality, patient satisfaction, quality of life, and resource utilization). Moderate-strength evidence indicates that pharmacist-led chronic disease management increases goal attainment for HbA1c, blood pressure, and cholesterol levels. Moderate- or low-strength evidence also indicates that pharmacist-led chronic disease management and usual care were similar for urgent care visits or hospitalizations, clinical events, and adherence to medications. Evidence was insufficient for patient satisfaction. There was little reporting of access to care and drug-related problems. These results suggest that future programs are likely to achieve intended laboratory and physiologic goals. However, to accurately assess health care value, future research studies and implementation projects that utilize intermediate laboratory and physiologic goals as measures of effectiveness need to be certain that these goals are clearly linked to improved patient outcomes including clinical events, satisfaction, access, hospitalizations, costs, medication adherence, and drug-related problems without undue harms and costs.