# METHODS

## TOPIC DEVELOPMENT

This topic was nominated by Heather Ourth, PharmD, VACO Pharmacy Benefits Management Program Manager, on behalf of the National Clinical Pharmacy Research Group, chartered by the VACO Clinical Pharmacy Practice Office of VACO Pharmacy Benefits Management (PBM). The evidence review examines the effectiveness (both clinical and economic) of pharmacist-led chronic disease management compared to usual care.

## SEARCH STRATEGY

We searched MEDLINE (Ovid), CINAHL, the Cochrane Library, and the International Pharmaceutical Abstracts (IPA) database for articles published from 1995 through June 2015. Our search was designed to identify studies that included control groups and was limited to studies enrolling adults and published in the English language. The search included the MeSH terms pharmacists, disease management, patient care, case management, patient education as topic, medication therapy management, drug interactions, drug therapy, drug monitoring, medication reconciliation, and patient care management. The full search strategies are presented in Appendix A. We obtained additional articles by hand-searching the reference lists of systematic reviews and other reports and from peer reviewer suggested references.

## STUDY SELECTION

Abstracts from MEDLINE (n=504) were independently reviewed in duplicate by investigators and research associates. Abstracts from the CINAHL database (n=5 unique to CINAHL), IPA (n=588), and Cochrane (n=245) were reviewed by a co-investigator or research associate. We included studies of any design (including quality improvement projects) reporting on the effectiveness or harms of pharmacist-led care in outpatient adults with, or at risk for developing, a chronic disease. We excluded the following:

- Studies that did not include outpatient adults with or at risk for a chronic disease,
- Studies that did not test an intervention that was pharmacist-led, where the pharmacist was responsible for a component of patient care and, if part of a collaborative care team, the contribution of the pharmacist could be distinguished from other team members
- Studies that did not involve interventions intended to manage or prevent one or more chronic disease(s),
- Studies without a comparator,
- Studies that did not take place in a healthcare facility in the US (eg, studies set in retail pharmacies), and
- Studies of anticoagulation clinics because pharmacist management is considered standard care.

Full-text reports of studies identified as potentially eligible were obtained for further review using the inclusion and exclusion criteria described above. Each article was independently reviewed by 2 investigators or research associates. Reasons for excluding a study at full text review were noted.

## DATA ABSTRACTION

Study characteristics (target population, inclusion/exclusion criteria, goal of intervention, primary outcome, duration/follow-up of study, type of pharmacist, study setting, intervention and comparator descriptions, and collaboration) as well as study-reported primary and secondary outcomes (drug-related problems, mortality, quality of life, access, patient satisfaction, healthcare utilization, cost, and goal attainment) were extracted onto evidence tables by one investigator or research associate and verified by another.

## RISK OF BIAS ASSESSMENT

We assessed the risk of bias based on the following criteria: sequence generation, allocation concealment, risk of bias from confounding (for non-randomized studies), blinding, incomplete outcome reporting, and selective outcome reporting – a modification of the Cochrane approach to determining risk of bias. (Higgins JPT, Green S, eds. Cochrane Handbook for Systematic Reviews of Intervention Version 5.1.0 [updated March 2011]. The Cochrane Collaboration, 2011. Available from www.cochrane-handbook.org.) Individual studies were rated as low, medium, or high risk of bias. Low risk of bias RCTs had adequate allocation concealment, blinding, and outcome reporting. Low risk of bias non-randomized studies also had low risk of bias from confounding.

## DATA SYNTHESIS

We organized evidence tables by disease state of the study population. We described and qualitatively compared the characteristics and findings of included studies. If pooling was feasible, data were analyzed in RevMan 5.3 (The Nordic Cochrane Center, Copenhagen, Denmark). Random effects models (DerSimonian-Laird) were used to calculate pooled risk ratios (RR) with 95% confidence intervals (CI) for categorical outcomes. However, pooled analyses were not possible for many outcomes due to heterogeneity of interventions and outcome reporting across studies. Therefore, most findings are summarized in narrative form.

## RATING THE BODY OF EVIDENCE

We rated the overall strength of the body of evidence for clinical events, patient satisfaction, target goal attainment, urgent care/emergency department visits and hospitalizations, and medication adherence using the method reported by Owens et al.10

## PEER REVIEW

A draft version of this report was reviewed by content experts as well as clinical leadership. Reviewer's comments and our responses are presented in Appendix B and the report has been modified as needed.