# RISK OF BIAS TABLES

Table 1 Risk of Bias for Cardiovascular Disease, Dyslipidemia, Chronic Obstructive Pulmonary Disease, and Chronic Kidney Disease Studies

Author, Year | Randomized? | Sequence Generation | Allocation Concealment | Risk of Bias from Confounding (non-randomized) | Blinding | Incomplete Outcome Reporting | Selective Reporting | Overall
Cardiovascular Disease or Risk Factors for Cardiovascular Disease
Taveira 2014 11 | Y | unclear | unclear | | unclear | low | low | Medium
Irons 2012 12 | N | | high | high | unclear | low | low | High
Coronary Artery Disease
Spence 2014 13 | N | | high | high | unclear | low | low | High
Olson 2009 14 | Y | low | unclear | | unclear | unclear | low | Medium
Congestive Heart Failure
Gattis 1999 15 | Y | low | unclear | | low | low | low | Low
Murray 2007 16 | Y | low | unclear | | low | unclear | low | Medium
Dyslipidemia
Smith 2013 54 | N | | high | low | unclear | low | low | Medium
Miller 2008 55 | N | | high | high | unclear | unclear | low | High
Mazzolini 2005 56 | N | | high | high | unclear | low | low | High
Straka 2005 57 | N | | high | high | unclear | low | low | High
Ellis 2000 58 | Y | high | low | | low | high | low | Medium
Bogden 1997 59 | Y | unclear | unclear | | unclear | low | low | Medium
Konzem 1997 60 | N | | low | high | unclear | low | high | High
Chronic Obstructive Pulmonary Disease
Cooney 2015 20 | Y | low | low | | low | unclear | low | Low
Aspinall 2012/2013^21,22^ | N | | unclear | high | unclear | low | low | Medium
Solomon 1998 23 Gourley 1998 24 | Y | low | unclear | | high | unclear | low | Medium
Chronic Kidney Disease
Pai 2009 (2 articles 18 ) 17 | Y (pilot) | low | low | | unclear | high | high | Medium
Bucaloiu 2007 19 | N | | low | high | unclear | low | low | Medium

Table 2 Risk of Bias for Depression Studies

Author, Year | Randomized? | Sequence Generation | Allocation Concealment | Risk of Bias from Confounding (non-randomized) | Blinding | Incomplete Outcome Reporting | Selective Reporting | Overall
Adler 2004 25 | Y | low | low | | low | high | low | Low
Capoccia 2004 26 | Y | unclear | unclear | | unclear | low | low | Medium
Finley 2003 28 | Y | unclear | low | | low | high | low | Medium
Finley 2002 29 | N | | high | high | low | high | low | High

Table 3 Risk of Bias for Diabetes Studies

Author, Year | Randomized? | Sequence Generation | Allocation Concealment | Risk of Bias from confounding (non-randomized) | Blinding | Incomplete Outcome Reporting | Selective Reporting | Overall
McAdam-Marx 2015 53 | N | | low | unclear | unclear | low | low | Medium
Rothman, 2005 39 | Y | low | low | | low | low | low | Low
Skinner 2015 35 | N | | low | low | unclear | low | low | Low
Chung, 2014 50 | N | | high | low | unclear | low | low | Medium
Spence, 2014 13 | N | | high | low | high | low | low | Medium
Brummel, 2013 46 | N | | high | high | unclear | low | low | High
Ip, 2013 43 | N | | unclear | low | unclear | low | low | Medium
Jacobs, 2012 38 | Y | low | low | | unclear | low | low | Low
Salvo, 2012 49 | N | | high | unclear | high | low | low | Medium
Cohen, 2011 32 | Y | unclear | unclear | | unclear | low | low | Medium
Padiyara, 2011 45 | N | | high | low | unclear | low | unclear | Medium
Pape, 2011 48 | Y | unclear | unclear | | unclear | high | low | Medium
Taveira, 2011 30 | Y | low | low | | unclear | low | low | Low
Heisler, 2010/2012^33,34^ | Y | low | low | | unclear | low | low | Low
Jameson, 2010 36 | Y | low | low | | unclear | low | low | High
Johnson, 2010 42 | N | | high | high | unclear | low | low | High
Taveira, 2010 31 | Y | unclear | unclear | | low | low | low | Medium
Fox, 2009 47 | N | | high | low | unclear | low | low | Medium
Scott, 2006 40 | Y | low | unclear | | unclear | unclear | low | Medium
Kelly, 2000 44 | N | | high | unclear | unclear | high | low | Medium
Odegard, 2005 51 | Y | unclear | unclear | | low | high | unclear | Medium
Shane-McWhorter, 2005 41 | N | | unclear | high | unclear | low | low | High
Stroup, 2003 52 | Y | unclear | unclear | | high | low | low | Medium
Jaber, 1996 37 | Y | unclear | unclear | | high | low | low | Medium

Table 4 Risk of Bias for Hypertension Studies

Author, Year | Randomized? | Sequence Generation | Allocation Concealment | Risk of Bias from confounding (non-randomized) | Blinding | Incomplete Outcome Reporting | Selective Reporting | Overall
Carter 2015 61 | Y | unclear | unclear | | unclear | low | low | Medium
Zillich 2015 66 | N | | low | low | unclear | low | Low | Low
Hirsch, 2014 69 | Y | low | unclear | NA | unclear^a^ | low | low | Medium
Magid 2013 70 | Y | low | unclear | NA | low | low | low | Medium
Margolis 2013 62 | Y cluster | unclear | unclear | NA | high | low | low | Medium
Magid 2011 67 | Y | low | unclear | NA | low | low | low | Medium
Carter 2009 63 | Y cluster | unclear | unclear | NA | unclear | low | low | Medium
Carter 2008 64 | Y cluster | unclear | unclear | NA | low | low | low | Medium
Green 2008 71 | Y | low | low | NA | low | low | low | Low
Hunt 2008 72 | Y | low | unclear | NA | low | high^b^ | low | Medium
Borenstein 2003 73 | Y | unclear | unclear | NA | unclear | low | low | Medium
Vivian 2002 68 | Y | unclear | unclear | NA | high | low | low | Medium
Okamoto 2001 75 | Y | unclear | unclear | NA | unclear | low | low | Medium
Solomon 1998 23 Gourley 1998 24 | Y | low | unclear | NA | high | unclear | low | Medium
Erickson 1997 65 | N | | high | high | unclear | high | low | High

a Potentially not blinded. Chart reviews were conducted by 2 clinical coordinators, one of whom was the study coordinator for this study.

b Very high attrition

Table 5 Risk of Bias for Polypharmacy Studies

Author, Year | Randomized? | Sequence Generation | Allocation Concealment | Risk of Bias from Confounding (non-randomized) | Blinding | Incomplete Outcome Reporting | Selective Reporting | Overall
Polypharmacy/High Risk
Lee 2006 77 | Y (Phase 2) | low | low | | high | low | low | Low
Taylor 2003 78 | Y | unclear | unclear | | unclear | high | low | Medium
Malone 2000 and 2001^79,80^ | Y | low | unclear | | low | high | low | Medium