# EVIDENCE TABLES

Table 1 Study and Intervention Characteristics – Cardiovascular Disease Studies

Table 2 Drug-related Problems Outcomes – Cardiovascular Disease Studies

Table 3 Mortality, Quality of Life, Access, and Patient Satisfaction Outcomes – Cardiovascular Disease Studies

Table 4 Healthcare Utilization and Cost Outcomes – Cardiovascular Disease Studies

Table 5 Goal Attainment Outcomes – Cardiovascular Disease Studies

Table 6 Study and Intervention Characteristics – Chronic Kidney Disease Studies

Table 7 Drug-related Problems Outcomes – Chronic Kidney Disease Studies

Table 8 Mortality, Quality of Life, Access, and Patient Satisfaction Outcomes – Chronic Kidney Disease Studies

Table 9 Healthcare Utilization and Cost Outcomes – Chronic Kidney Disease Studies

Table 10 Goal Attainment Outcomes – Chronic Kidney Disease Studies

Table 11 Study and Intervention Characteristics – Chronic Obstructive Pulmonary Disease Studies

Table 12 Drug-related Problems Outcomes – Chronic Obstructive Pulmonary Disease Studies

Table 13 Mortality, Quality of Life, Access, and Patient Satisfaction Outcomes – Chronic Obstructive Pulmonary Disease Studies

Table 14 Healthcare Utilization and Cost Outcomes – Chronic Obstructive Pulmonary Disease Studies

Table 15 Goal Attainment Outcomes – Chronic Obstructive Pulmonary Disease Studies

Table 16 Study and Intervention Characteristics – Depression Studies

Table 17 Drug-related Problems Outcomes – Depression Studies

Table 18 Mortality, Quality of Life, Access, and Patient Satisfaction Outcomes – Depression Studies

Table 19 Healthcare Utilization and Cost Outcomes – Depression Studies

Table 20 Goal Attainment Outcomes – Depression Studies

Table 21 Study and Intervention Characteristics – Diabetes Studies

Table 22 Drug-related Problems Outcomes – Diabetes Studies

Table 23 Mortality, Quality of Life, Access, and Patient Satisfaction Outcomes – Diabetes Studies

Table 24 Healthcare Utilization and Cost Outcomes – Diabetes Studies

Table 25 Goal Attainment Outcomes – Diabetes Studies

Table 26 Study and Intervention Characteristics – Dyslipidemia Studies

Table 27 Drug-related Problems Outcomes – Dyslipidemia Studies

Table 28 Mortality, Quality of Life, Access, and Patient Satisfaction Outcomes – Dyslipidemia Studies

Table 29 Healthcare Utilization and Cost Outcomes – Dyslipidemia Studies

Table 30 Goal Attainment Outcomes – Dyslipidemia Studies

Table 31 Study and Intervention Characteristics – Hypertension Studies

Table 32 Drug-related Problems Outcomes – Hypertension Studies

Table 33 Mortality, Quality of Life, Access, and Patient Satisfaction Outcomes – Hypertension Studies

Table 34 Healthcare Utilization and Cost Outcomes – Hypertension Studies

Table 35 Goal Attainment Outcomes – Hypertension Studies

Table 36 Study and Intervention Characteristics – Polypharmacy/High Risk Studies

Table 37 Drug-related Problems Outcomes – Polypharmacy/High Risk Studies

Table 38 Mortality, Quality of Life, Access, and Patient Satisfaction Outcomes – Polypharmacy/High Risk Studies

Table 39 Healthcare Utilization and Cost Outcomes – Polypharmacy/High Risk Studies

Table 40 Goal Attainment Outcomes – Polypharmacy/High Risk Studies