# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Reviewer Comments Export

Pharmacist-led Chronic Disease Management: A Systematic Review of Effectiveness and Harms Compared to Usual Care
Question Text | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence? | | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | Yes - only in the Executive Summary | Please see below for our response
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | Yes - Description of bias noted in review comments | Please see below for our response
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence? | | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | Yes - Based on your search strategy, I would have thought that a VA study which compared pharmacist-managed ESA clinic (for CKD) would have been included in the section of CKD. References below. (disclosure- I am one of the authors. Having said that, I really don't care if this study is included, if there is good reason why it should not be included.) 1. Aspinall SL, Cunningham FE, Zhao X, Boresi JS, Tonnu-Mihara IQ, Smith KJ, Stone RA, Good CB. Impact of pharmacist-managed erythropoiesis-stimulating agents clinics for non-dialysis chronic kidney disease patients. Am J Kidney Dis 2012; 60 (3): 371-9. PMID 22633556 2. Aspinall SL, Smith KJ, Good CB, Zhao X, Stone RA, Tonnu-Mihara IQ, Cunningham R, for the ESA Clinic Study Group. Incremental cost-effectiveness of pharmacist-managed erythropoietin-stimulating agent clinics for non-dialysis-dependent chronic kidney disease. Appl Health Econ and Health Policy 2013; 11:653-660. | Thank you for identifying this study. We have added the 2 articles to our review.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | Yes - Recommendations noted in review comments. | Thank you. Please see below for our response.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Three Comments 1) The report mentions in several sections the concern that while attaining many targets better in pharmacy intervention arms, compared to control- those targets have not been shown to improve clinical outcomes, and may actually be associated with harm. I find this somewhat curious- indeed, this is true. But, it is true in hindsight-at the time most of these studies were done, it was generally accepted that these targets were clinically relevant (for instance, that HBA1C of less than 7 was an important target). So, to criticize those intermediate outcomes seems unfair. Indeed, the pharmacists in those studies accomplished what they were asked to accomplish. Today, we would design those studies differently, but we have evidence that came after the referenced studies were done. Furthermore, the fact that most of the studies only demonstrate intermediate outcomes really reflects the roll of the clinical pharmacist in the clinic. Most of the studies were relatively short term, reflecting the reason patients are sent for clinical pharmacist input- usually goal directed (improve blood pressure control, etc). | 1) We have limited our review to the findings of the studies, and rephrased our Limitations and Conclusions
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2. I did not have time to pull individual articles, but I did pull several. Randomly, I looked at the Gattis article. It is published in a reputable journal. In the text, the study is referenced as showing no significant difference in clinical outcomes (overall mortality) but the study reports sig decrease in mortality plus heart failure events. If this outcome was not valid, I feel it should have been clear in the report that while the study reported a clinically relevant improvement in outcome, these were not accepted because of……(In the tables, it shows up under hospitalizations…being significantly less). | 2. The combination outcome from the Gattis article was reported on the Evidence Table in the Appendix but was not carried forward accurately to the report. We have made that change.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3. The review was also intended to evaluate harms. However, “harms” is almost never mentioned throughout the report. Harms are not specifically mentioned in the Executive Summary, and in the individual sections, adverse events are identified as a gap area. However, this is not clearly articulated as seeking evidence for “harms”. Suggest explicitly discussing “harms”- which I assume that there is little evidence to address in the review. | 3. Although systematic reviews do have different criteria for evidence of harm, there was insufficient evidence on harms as most studies didn't report harms and those that did often didn't report data for the control group.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | The information presented in the report is well constructed and comprehensive in its review of the topic. | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | The research question is concise and well formulated. The summary and analysis of reviewed/considered data upon which an attempted answer to the question is based is objectively and accurately presented.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | As a reader/reviewer, I was generally able to understand the distinctions between various measured/evaluated parameters. However, the listing of one or two relevant examples of the authors' “definition” of “clinical events” (within a disease being examined) in relationship to the broader “clinical outcomes” of interest across all disease types (which are explicitly stated) would likely be helpful to future readers and users of the report. That is, what specific thing might qualify as an example of a “clinical event” in the care and treatment of a patient with the specified disease under scrutiny. Most other definitions, measures, and examples are more clearly detailed. | We have added some examples of “clinical events” in the listing of outcomes of interest and as a footnote to the Strength of Evidence tables..
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | My impression from this systematic review is that pharmacists are not yet good at designing studies and choosing or measuring the outcomes the reviewers deem important. It may be that pharmacist-led team have not been numerous enough or in existence long enough to reach important mortality end points. A more complete description of the evolution of pharmacists from product preparation to patient providers may be helpful. The papers they reviewed were very heterogeneous and not powered to detect the outcomes this review considered most important (e.g. mortality, resource use, access, satisfaction). Nevertheless, they show that pharmacist provided care is for the most part not different from non-pharmacist with goal attainment (LDL, HgbA1c, BP) being better with pharmacist provided care. In the executive summary these facts were presented in a very negative light. For example, on actual page 35, study page 23 paragraph 1 under key findings: they drew conclusions about pharmacist-led care not improving outcomes for depression but specifically stated “studies were not always adequately designed or analyzed for these outcomes”. If that is the case, state lack of study design but do not move to a broader conclusion. | We agree that published studies were not designed to assess mortality and clinical events or authors did not report these findings
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | | We would note that most of the included studies looked at the addition of pharmacist-led care to usual care, not pharmacist-led care versus non-pharmacist care.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | | We have rephrased the conclusions about the depression studies.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | My global impression is that this systemic review including categorization, inclusion/exclusion etc. is sound but the way the results are interpreted and the wording of their summary/discussion/conclusion can be improved. The way it is now stated, can be misinterpreted and shed a negative light on what pharmacists have done to date. Specifically, the part on goal attainment which actually showed that pharmacists provided care did better in this category. But, this is undermined by saying that these goals are less strict now anyway and there isn't a strong evidence that attaining these goals are clinically meaningful. While this may be true, it did not represent the evidence/guidance at the time which is a more global issue. | We have modified the wording of the Limitations and Conclusions sections.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Edits: Actual page 54, study page 41, paragraph 4, line 3: “further study is needed” change to- further studies are needed Actual page 38, study page 26, paragraph 4, line 4: “Two studied reported no significant differences” change to- Two studies reported | Edits: Thank you. We have made changes to these sentences.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | The authors have conducted an extensive evidence-based review of Pharmacist-led Chronic Disease Management, particularly as it relates to effectiveness of care. The technical accuracy of the effectiveness of care review meets the evidence-based standards described in the report's methodology. It is noted that the findings of this effectiveness of care review are similar to the 2014 systematic review of outpatient medication therapy management (MTM) interventions conducted by Viswanathan, et. al. (2014 AHRQ review). These similarities would be expected as both analyses used similar evidence-based criteria arriving at a conclusion of difficulty interpreting findings due to heterogeneity of services and interventions. The purpose of this review is to provide the authors, and the Veterans Health Administration, with suggestions and recommendations for improving this ESP review as it pertains to the methodology employed, and implications and applicability of the evidence-based findings contained in this review.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | -First, it would be helpful to the reader to frame the findings of this review in the context of evidence-based reviews of physicians, and other health professionals, chronic disease management services. In its present state, there is no frame of reference or context for understanding the findings of this report. Are these results similar or different than other evidence-based findings of chronic disease management provided by other health care professionals, as well as team-based care? | 1) Our findings were based on the available evidence regarding pharmacist-led clinics. Other disease management clinics also frequently use measures such as “goal attainment.” We believe we have assessed the most clinically relevant endpoints and initially discussed these with our Technical Expert Panel. There are few studies comparing pharmacist-led chronic disease management to other health care professionals. Thus, we hesitate to draw any conclusions about whether pharmacists provide more or less value.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | -Second is a critique of the Review of Harms. It is greatly appreciated that the report's Conclusions highlight the importance of achieving patient-specific treatment goals by noting that; ‘studies of pharmacist-led care generally achieved intermediate target thresholds designed to achieve a “goal attainment” that should be done cautiously to provide patient-centered high value health care.’ This is the essence of comprehensive team-based medication management in an era of accountable health care. However, it is repeatedly stated in the report that, “achieving target goals for HbA1c, blood pressure, and cholesterol reported in the included studies have not been convincingly demonstrated to improve health outcomes but can increase harms and costs.” If this statement is to be made, the evidence supporting this finding needs to be presented. The authors will need to summarize the results of other studies in which achieving intermediate target thresholds can cause harms (e.g. A1c < 7% in the elderly, LDL < 70 mg/dl in octogenarians, etc.). In fact, unless additional evidence-based studies describing harms from aggressively achieving intermediate target thresholds can be described, then it is strongly recommended that the report title be corrected to remove the word HARMS, because a systematic evidence-based review of harms is not apparent in this analysis. | 2) We have modified the Limitations and Conclusions.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | | Regarding harms, please see response above.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | -Third, is an inherent bias in the report pertaining to use of an outcome measure without a published taxonomy or official nomenclature. It is understood that the term, “Drug-related Problems” is commonly used in the literature, however there is no published classification system for this term. On the other hand, a published taxonomy of Drug Therapy Problems is available in the National Library of Medicine. One suggestion for improving the report is to utilize the four main published categories of Drug Therapy Problems (e.g. indication, effectiveness, safety, and convenience/adherence) to frame the analysis of drug-related problems. And one other item, on page 14, line 28 there is a statement in regards to the CKD RCT that “drug-related problems were not reported for the control group.” Without clarification this may be an irresponsible statement. No human subjects protection program or Institutional Review Board would approve a study in which drug therapy problems were identified in a control group without taking appropriate actions to resolve drug therapy problems in the control group of patients. In Medicine, this would be analogous to identifying a medical condition in a control patient and not doing anything about it. | 3) Our list of medication outcomes of interest was approved by our Technical Expert Panel members. We have defined our meaning of “drug-related problems” and removed the term “drug therapy problems” from the review.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | | We have modified the text so the statement about drug-related problems in the control group has been deleted. It would have been more accurate to state that the drug related problems in the control group were not reported in the manuscript.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | -Fourth, it is noted that the evaluation approach employed in this analysis is deeply vested in experimental design that dominates the toolkit of evidence-based medicine. This evaluation approach has been summarized by Pawson and Tilley as an, OXO design: observe a system (O), introduce a perturbation/intervention (X) to some participants but not others, and then observe again (O). [1] Pawson and Tilley assert that when studies use the OXO paradigm to evaluate social programs (including most system improvements in medicine), the result is almost always “a heroic failure, promising so much and yet ending up in ironic anticlimax. The underlying logic seems meticulous, clear-headed and militarily precise, and yet findings seem to emerge in a typically non-cumulative, low-impact, prone-to-equivocation sort of way.” The usual conclusion and assertion from traditional OXO evaluations of quality-improvement efforts in health care is either that nothing works or that the results are inconsistent and more research is needed. [1] Dr. Don Berwick, former CMS Administrator and champion of the Science of Quality Improvement, has stated that the OXO paradigm most commonly applied in the traditional toolkit of evidence-based medicine is, “a powerful, perhaps unequaled, research design to explore the efficacy of conceptually neat components of clinical practice—tests, drugs, and procedures. For other crucially important learning purposes, however, it serves less well.” [2] The introduction of interprofessional and interdisciplinary chronic care management systems for establishing a rational medication use system in which pharmacists work with patients to achieve their goals of therapy with zero tolerance for preventable medication harms is a complex, multicomponent intervention—essentially a process of social change. Pawson and Tilley claim that the reason the OXO model fails in this context is because, “experimentalists have pursued too single-mindedly the question of whether a program works at the expense of knowing why it works.” [1] | 4) We evaluated studies that were specifically designed to assess the effectiveness of pharmacist-led chronic disease management. We included many study types including those often used in quality improvement initiatives (as many of these were). We disagree that we held pharmacist-led CDM to “too demanding” quality. Our charge was to conduct a systematic review focusing on the highest quality evidence available, ie, controlled clinical trials. Implementation should require evidence of effectiveness that exceeds harms and costs (ie, high value). The studies we reviewed did not provide convincing evidence about the value of pharmacist-led care.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | The fifth and final area of improvement relates to the implications and applicability of findings within the Veterans Health Administration system. This is to say, that it would be very helpful to address the, “so what question” of the report's findings. In many of the VISN regions of the VA system, there are exemplary pharmacist-led chronic care advances and innovations supported by evidence of improved quality of care. One of the most important topics that is not addressed in this report is reducing pharmacist-led care process variations across the VA VISN's. The science of continuous quality improvement (e.g. statistical process controls, run charts, etc.) provides the tools, techniques and measures to achieve this urgent national need in the care of this country's Veterans. Thank you for the opportunity to serve as an external review for this Evidence-based Report. References: 1.) Pawson R, Tilley N. Realistic Evaluation. London, England: Sage Publications Ltd; 1997. 2.) Berwick DM. The Science of Improvement. JAMA. 2008;299(10):1182-1184. doi:10.1001/jama.299.10.1182 | 5) We agree that implications and applicability are important, however, our purpose is to provide a review of evidence for VA policy makers. It is also outside of the scope of this review to address the question of variation in practice across VA VISNs. We highlighted studies conducted in the VA system and are not aware of any other evidence of improved quality of care.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | This is excellent work. My only comment is that I continue to urge the authors to phrase their findings carefully to avoid giving the impression that pharmacist-led care has been shown not to improve outcomes such as mortality. Rather, as the aphorism goes, absence of evidence should not be construed as evidence of absence. That is, the studies have not been done to evaluate those outcomes. This should be made clear. | Thank you. We agree and have reviewed our wording to be clear on the absence of evidence for key outcomes.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | This is a very thorough and well done report. Several comments: | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1. Pg. 5, lines 11-12 It is important to clarify these statements to state that in certain patients the more intensive treatment targets may cause harm, but not all patients as the statement reads now. Also, not all patients require less intensive treatment targets. Those recommendations apply to certain high-risk patients (especially in diabetes) whereas this statement implies that all patients would require less intensive targets. | 1. We have modified this section.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2. Pg. 19, Table 3, line 12 The 1 does not have a key corresponding with this and I believe it should be a ‘b’ instead. | 2. We have made the correction
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3. Pg. 23, line 24-25 This statements says there were 3 RCT's but lists 4 references and again in lines 38 & 39 it talks about 2 studies but lists 3 references. Clarification here would be helpful. | 3. The 3 RCTs were reported in 4 papers. We have clarified this at the start of the paragraph.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4. Pg. 28, Figure 6 The placement of this figure is a bit confusing as it is in the middle of the diabetes study discussion but it combines the lipids, hypertension and polypharmacy studies with the diabetes. It may make more sense to put at the end after review of each of those sections. | 4. We have placed Figure 6 in the Diabetes section because that is where the first reference to the figure is located. We again refer to Figure 6 in the lipids, hypertension, and polypharmacy sections.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5. Pg. 29, line 54 The dyslipidemia heading lists 2 RCTs, 2 CCTs, and 2 Cohort studies while the text discusses 7 studies (line 54). | 5. We have corrected/clarified the count of studies for the Dyslipidemia section.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6. Pg. 33, line 14 “in the” is written twice. | 6. Thank you, we have made this edit.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 7. Pg. 39, lines 28-31. See comment #1 above as the same applies in this section and also on Pg. 42, lines 21 & 22. | 7. We have modified the wording on treatment targets throughout the report.