# SEARCH STRATEGIES

## MEDLINE (OVID)

1. Pharmacists/ or pharmacist:.ti,ab.
2. (pharmaceutical care or pharmaceutical services or community pharmac: or clinical pharmac:).ti,ab.
3. 1 or 2
4. Patient care/ or patient care management/
5. Collaborative care.mp. or exp patient care planning/ or intervention:.mp.
6. Case management/ or case management.mp. or care management.mp
7. Disease management/ or disease management.mp. or (disease adj3 prevent:).mp.
8. (chronic disease adj3 management).mp.
9. (chronic disease adj3 prevent:).mp.
10. Chronic care improvement.mp.
11. 4 or 5 or 6 or 7 or 8 or 9 or 10
12. 3 and 11
13. Chronic disease/
14. (chronic adj3 condition:).mp.
15. Exp pulmonary disease, chronic obstructive/
16. Congestive heart failure.mp. or heart failure/ or exp heart failure/
17. Dyslipidemia.mp. or exp dyslipidemia/
18. Diabetes.mp.
19. Hypertension.mp. or exp hypertension/
20. Cancer.mp. or exp neoplasms/
21. Kidney disease.mp. or kidney diseases/ or exp kidney diseases/ or kidney failure.mp.
22. Chronic pain.mp.
23. Depression.mp. or exp depressive disorder/
24. 12 or 14 or 15 or 16 or 18 or 19 or 20 or 21 or 22 or 23
25. Outpatient/ or outpatient:.mp. or outpatient.ti,ab.
26. Ambulatory.mp.
27. Assisted living facilities/ or assisted living.mp.
28. Primary care:.mp.
29. Primary health care/
30. Community pharmac:.mp.
31. Outpatient clinics, hospital/ or clinic.mp.
32. Office visits/ or community health services/ or clinics.mp.
33. 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32
34. 12 and 24 and 33
35. Limit 34 to (English language and yr=”1995-current”)
36. Limit 35 to “all child (0 to 18 years)”
37. Limit 36 to “all adult (19 plus years)”
38. 36 not 37
39. 35 not 38
40. Limit 39 to (meta analysis or systematic reviews)
41. Limit 39 to (controlled clinical trial or randomized controlled trial)
42. Comparative study/
43. 39 and 42
44. Control group.mp.
45. (control: or compar: or random:).ti,ab.
46. 44 or 45
47. 39 and 46
48. 41 or 43 or 47

## CINAHL

1. Pharmacist* OR MH pharmacists
2. (pharmaceutical W1 (care or service?)) OR ((community or clinical) W1 pharmac*) OR collaborative W1 care OR intervention* OR ((care or case) W1 management)
3. Disease N1 management OR disease N3 prevent* OR ((chronic W1 disease) N3 (management or prevent*)) OR chronic W1 care W1 improvement
4. (MH “Case Management”) OR (MH “Disease Management”)
5. 2 or 3 or 4
6. Chronic N3 condition* OR congestive W1 heart W1 failure OR dyslipidemia OR diabetes OR hypertension OR cancer
7. Kidney N1 disease* OR kidney N1 fail* OR chronic N1 pain OR depression
8. (MH “Kidney Diseases+”) OR (MH “Chronic Pain”) OR (MH “Depression+”)
9. 6 or 7 or 8
10. Outpatient* OR ambulatory OR assisted W1 living OR primary W1 care OR community W1 pharmac* OR clinic?
11. (MH “Outpatients”) OR (MH “Ambulatory Care”) OR (MH “Ambulatory Care Facilities+”) OR (MH “Assisted Living”) OR (MH “Primary Health Care”) OR (MH “Community Health Centers”)
12. 10 or 11
13. 1 and 5
14. (MH “Office Visits”)
15. Office W1 visit*
16. 12 or 14 or 15
17. 9 and 13 and 16
18. 9 and 13 and 16 (limiters- randomized controlled trials, Search modes-find all my search terms
19. “meta analysis” OR “systematic review” OR “controlled clinical trial” OR :comparative study” OR “control group” OR control* OR compar* OR random* (limiters-randomized controlled trials, search modes- find all my search terms)
20. (MH “Meta Analysis”) OR (MH “Systematic review”) OR (MH “Clinical Trials+”) OR (MH “Comparative Studies”) OR (MH “Control Group”)
21. 19 or 20
22. 17 and 21
23. 18 or 22
24. 18 or 22 (limiters- published date: 19950101-20150131; English Language; Exclude MEDLINE records; Human; Age Groups: All Adult, search modes-Find all my search terms)

## COCHRANE LIBRARY

1. Pharmacist*
2. Pharmaceutical next (care or service)
3. Collaborative next care
4. Intervention*
5. (care or case) next management
6. Disease near management
7. Disease near prevent*
8. (chronic next disease) near (management or prevent*)
9. Patient care:kw
10. MeSH descriptor: [Chronic Disease] explode all trees
11. MeSH descriptor: [Patient Care Planning] explode all trees
12. #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11
13. #1 and #12
14. Chronic near condition?
15. Congestive next heart next failure
16. Dyslipidemia or diabetes or hypertension or cancer?
17. Kidney next disease?
18. Kidney next fail*
19. Chronic next pain
20. Depression
21. MeSH descriptor: [heart Failure] explode all trees
22. MeSH descriptor: [Pulmonary Disease, Chronic Obstructive] explode all trees
23. MeSH descriptor: [Dyslipidemias] explode all trees
24. MeSH descriptor: [Diabetes Mellitus] explode all trees
25. MeSH descriptor: [Neoplasms] explode all trees
26. MeSH descriptor [kidney diseases] explode all trees
27. MeSH descriptor: [depressive disorder] explode all trees
28. #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27
29. #13 and #28
30. Outpatient? Or ambulatory or clinic?
31. Assisted near living
32. Primary next care
33. Community next pharmac*
34. Primary health care:kw
35. Outpatient clinics, hospital:kw
36. Office visits:kw
37. Community health services:kw
38. #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37
39. #29 and #38
  Publication Year from 1995 to 2015

## INTERNATIONAL PHARMACEUTICAL ABSTRACTS (IPA)

1. pharmacists/ or pharmacist:.ti,ab.
2. (pharmaceutical care or community pharmacy or clinical pharmac:).ti,ab.
3. 1 or 2
4. patient care/ or patient care management/
5. case management/ or case management.mp. or care management.mp.
6. patient education as topic/ or counsel:.mp.
7. disease management/ or disease management.mp. or (disease adj3 prevent:).mp.
8. medication therapy management/ or (medication adj3 management).mp.
9. (prescription adj3 management).mp.
10. medication optimiz:.mp. or drug interactions/ or therapeutic plan.mp.
11. prescription optimiz:.mp.
12. dt.fs. or drug therapy/ or medication counseling.mp.
13. prescription counseling.mp.
14. drug monitoring/ or prescription monitor:.mp. or drug monitor:.mp.
15. medication surveillance.mp. or medication reconciliation/ or prescription reconciliation.mp.
16. ((medication adj3 review) or (prescription adj3 review) or (drug adj3 review)).mp.
17. 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16
18. 3 and 17
19. limit 18 to (english language and yr=“1995 -Current”)
20. limit 19 to journal articles
21. Comparative Study/
22. control group.mp.
23. (control: or compar: or random:).ti,ab.
24. study design.ti,ab.
25. 22 or 23 or 24
26. 20 and 25
27. outpatient/ or outpatient:.mp.
28. ambulatory.mp.
29. urgent care.mp.
30. emergency:.mp.
31. assisted living facilities/ or assisted living.mp.
32. primary care:.mp.
33. community:.mp.
34. 27 or 28 or 29 or 30 or 31 or 32 or 33
35. 26 and 34