# References

1 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. 2011; http://handbook.cochrane.org/. Accessed March 24, 2017.
2 Review Manager (RevMan) [Computer program]. Version 5.3. Copenhagen: The Nordic Cochrane Centre, The Cochrane Collaboration, 2014.
3 Karila L, Weinstein A, Aubin H-J, Benyamina A, Reynaud M, Batki SL. Pharmacological approaches to methamphetamine dependence: a focused review. British journal of clinical pharmacology. 2010;69(6):578–592.20565449
4 Singh M, Keer D, Klimas J, Wood E, Werb D. Topiramate for cocaine dependence: a systematic review and meta-analysis of randomized controlled trials. Addiction (Abingdon, England). 2016;111(8):1337–1346.
5 Castells X, Cunill R, Perez-Mana C, Vidal X, Capella D. Psychostimulant drugs for cocaine dependence. The Cochrane database of systematic reviews. 2016;9:CD007380.27670244
6 Elkashef A, Vocci F, Hanson G, White J, Wickes W, Tiihonen J. Pharmacotherapy of methamphetamine addiction: An update. Substance Abuse. 2008;29(3):31–49.19042205
7 NIH. What are the long-term effects of cocaine use? 2016. Accessed October 10, 2017, 2017.
8 Treadwell JR, Singh S, Talati R, McPheeters ML, Reston JT. AHRQ Methods for Effective Health Care. In: A Framework for “Best Evidence” Approaches in Systematic Reviews. Rockville (MD): Agency for Healthcare Research and Quality (US); 2011.
9 Wallace BC, Small K, Brodley CE, Lau J, Trikalinos TA. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the 2nd ACM SIGHIT International Health Informatics Symposium (IHI). 2012:819–824.
10 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Rockville, MD: Agency for Healthcare Research and Quality; Methods Guide for Comparative Effectiveness Reviews (AHRQ Publication No. 13(14)-EHC130-EF);2013.
11 Castells X, Kosten TR, Capella D, Vidal X, Colom J, Casas M. Efficacy of opiate maintenance therapy and adjunctive interventions for opioid dependence with comorbid cocaine use disorders: A systematic review and meta-analysis of controlled clinical trials. The American journal of drug and alcohol abuse. 2009;35(5):339–349.20180662
12 Indave BI, Minozzi S, Pani PP, Amato L. Antipsychotic medications for cocaine dependence. The Cochrane database of systematic reviews. 2016;3:CD006306.26992929
13 Minozzi S, Amato L, Pani PP, . Dopamine agonists for the treatment of cocaine dependence. The Cochrane database of systematic reviews. 2015(5):CD003352.26014366
14 Minozzi S, Cinquini M, Amato L, . Anticonvulsants for cocaine dependence. The Cochrane database of systematic reviews. 2015(4):CD006754.
15 Pani PP, Trogu E, Vacca R, Amato L, Vecchi S, Davoli M. Disulfiram for the treatment of cocaine dependence. The Cochrane database of systematic reviews. 2010(1):CD007024.20091613
16 Pani PP, Trogu E, Vecchi S, Amato L. Antidepressants for cocaine dependence and problematic cocaine use. The Cochrane database of systematic reviews. 2011(12):CD002950.22161371
17 Afshar M, Knapp CM, Sarid-Segal O, . The efficacy of mirtazapine in the treatment of cocaine dependence with comorbid depression. The American journal of drug and alcohol abuse. 2012;38(2):181–186.22221171
18 Baldacara L, Cogo-Moreira H, Parreira BL, . Efficacy of topiramate in the treatment of crack cocaine dependence: a double-blind, randomized, placebo-controlled trial. The Journal of clinical psychiatry. 2016;77(3):398–406.27046312
19 Bisaga A, Aharonovich E, Cheng WY, . A placebo-controlled trial of memantine for cocaine dependence with high-value voucher incentives during a pre-randomization lead-in period. Drug and alcohol dependence. 2010;111(1–2):97–104.20537812
20 Carroll KM, Nich C, Petry NM, Eagan DA, Shi JM, Ball SA. A randomized factorial trial of disulfiram and contingency management to enhance cognitive behavioral therapy for cocaine dependence. Drug and alcohol dependence. 2016;160:135–142.26817621
21 Carroll KM, Nich C, Shi JM, Eagan D, Ball SA. Efficacy of disulfiram and Twelve Step Facilitation in cocaine-dependent individuals maintained on methadone: a randomized placebo-controlled trial. Drug and alcohol dependence. 2012;126(1–2):224–231.22695473
22 Gilgun-Sherki Y, Eliaz RE, McCann DJ, . Placebo-controlled evaluation of a bioengineered, cocaine-metabolizing fusion protein, TV-1380 (AlbuBChE), in the treatment of cocaine dependence. Drug and alcohol dependence. 2016;166:13–20.27394932
23 Hersh D, Van Kirk JR, Kranzler HR. Naltrexone treatment of comorbid alcohol and cocaine use disorders. Psychopharmacology. 1998;139(1–2):44–52.9768541
24 Johnson BA, Roache JD, Ait-Daoud N, . A preliminary randomized, double-blind, placebo-controlled study of the safety and efficacy of ondansetron in the treatment of cocaine dependence. Drug and alcohol dependence. 2006;84(3):256–263.16631323
25 Kablinger AS, Lindner MA, Casso S, . Effects of the combination of metyrapone and oxazepam on cocaine craving and cocaine taking: a double-blind, randomized, placebo-controlled pilot study. Journal of psychopharmacology (Oxford, England). 2012;26(7):973–981.
26 Kahn R, Biswas K, Childress A-R, . Multi-center trial of baclofen for abstinence initiation in severe cocaine-dependent individuals. Drug and alcohol dependence. 2009;103(1–2):59–64.19414226
27 Kampman K, Majewska MD, Tourian K, . A pilot trial of piracetam and ginkgo biloba for the treatment of cocaine dependence. Addictive behaviors. 2003;28(3):437–448.12628617
28 Kampman KM, Dackis C, Pettinati HM, Lynch KG, Sparkman T, O’Brien CP. A double-blind, placebo-controlled pilot trial of acamprosate for the treatment of cocaine dependence. Addictive behaviors. 2011;36(3):217–221.21112155
29 Kampman KM, Volpicelli JR, Mulvaney F, . Effectiveness of propranolol for cocaine dependence treatment may depend on cocaine withdrawal symptom severity. Drug and alcohol dependence. 2001;63(1):69–78.11297832
30 Kennedy AP, Gross RE, Whitfield N, Drexler KPG, Kilts CD. A controlled trial of the adjunct use of D-cycloserine to facilitate cognitive behavioral therapy outcomes in a cocaine-dependent population. Addictive behaviors. 2012;37(8):900–907.22578380
31 Kosten TR, Wu G, Huang W, . Pharmacogenetic randomized trial for cocaine abuse: disulfiram and dopamine beta-hydroxylase. Biological psychiatry. 2013;73(3):219–224.22906516
32 LaRowe SD, Kalivas PW, Nicholas JS, Randall PK, Mardikian PN, Malcolm RJ. A double-blind placebo-controlled trial of N-acetylcysteine in the treatment of cocaine dependence. The American journal on addictions. 2013;22(5):443–452.23952889
33 Licata SC, Penetar DM, Ravichandran C, . Effects of daily treatment with citicoline: a double-blind, placebo-controlled study in cocaine-dependent volunteers. Journal of addiction medicine. 2011;5(1):57–64.21769048
34 Ling W, Hillhouse MP, Saxon AJ, . Buprenorphine + naloxone plus naltrexone for the treatment of cocaine dependence: the Cocaine Use Reduction with Buprenorphine (CURB) study. Addiction (Abingdon, England). 2016;111(8):1416–1427.
35 Malcolm R, LaRowe S, Cochran K, . A controlled trial of amlodipine for cocaine dependence: a negative report. Journal of substance abuse treatment. 2005;28(2):197–204.15780550
36 Mancino MJ, McGaugh J, Chopra MP, . Clinical efficacy of sertraline alone and augmented with gabapentin in recently abstinent cocaine-dependent patients with depressive symptoms. Journal of clinical psychopharmacology. 2014;34(2):234–239.24525654
37 Margolin A, Kantak K, Copenhaver M, Avants SK. A preliminary, controlled investigation of magnesium L-aspartate hydrochloride for illicit cocaine and opiate use in methadone-maintained patients. Journal of addictive diseases. 2003;22(2):49–61.12703668
38 Mariani JJ, Pavlicova M, Bisaga A, Nunes EV, Brooks DJ, Levin FR. Extended-release mixed amphetamine salts and topiramate for cocaine dependence: a randomized controlled trial. Biological psychiatry. 2012;72(11):950–956.22795453
39 Moran LM, Phillips KA, Kowalczyk WJ, . Aripiprazole for cocaine abstinence: a randomized-controlled trial with ecological momentary assessment. Behavioural pharmacology. 2017;28(1):63–73.27755017
40 Oliveto A, Poling J, Mancino MJ, . Randomized, double blind, placebo-controlled trial of disulfiram for the treatment of cocaine dependence in methadone-stabilized patients. Drug and alcohol dependence. 2011;113(2–3):184–191.20828943
41 Oliveto A, Poling J, Mancino MJ, . Sertraline delays relapse in recently abstinent cocaine-dependent patients with depressive symptoms. Addiction (Abingdon, England). 2012;107(1):131–141.
42 Pettinati HM, Kampman KM, Lynch KG, . A pilot trial of injectable, extended-release naltrexone for the treatment of co-occurring cocaine and alcohol dependence. The American journal on addictions. 2014;23(6):591–597.25251201
43 Pettinati HM, Kampman KM, Lynch KG, . Gender differences with high-dose naltrexone in patients with co-occurring cocaine and alcohol dependence. Journal of substance abuse treatment. 2008;34(4):378–390.17664051
44 Plebani JG, Lynch KG, Yu Q, Pettinati HM, O’Brien CP, Kampman KM. Results of an initial clinical trial of varenicline for the treatment of cocaine dependence. Drug and alcohol dependence. 2012;121(1–2):163–166.21925806
45 Poling J, Rounsaville B, Gonsai K, Severino K, Sofuoglu M. The safety and efficacy of varenicline in cocaine using smokers maintained on methadone: a pilot study. The American journal on addictions. 2010;19(5):401–408.20716302
46 Raby WN, Rubin EA, Garawi F, . A randomized, double-blind, placebo-controlled trial of venlafaxine for the treatment of depressed cocaine-dependent patients. The American journal on addictions. 2014;23(1):68–75.24313244
47 Reid MS, Angrist B, Baker S, . A placebo-controlled screening trial of celecoxib for the treatment of cocaine dependence. Addiction (Abingdon, England). 2005;100: Suppl 1:32–42.
48 Reid MS, Angrist B, Baker SA, . A placebo controlled, double-blind study of mecamylamine treatment for cocaine dependence in patients enrolled in an opiate replacement program. Substance abuse. 2005;26(2):5–14.
49 Schmitz JM, Green CE, Hasan KM, . PPAR-gamma agonist pioglitazone modifies craving intensity and brain white matter integrity in patients with primary cocaine use disorder: a double-blind randomized controlled pilot trial. Addiction (Abingdon, England). 2017;112(10):1861–1868.
50 Schmitz JM, Lindsay JA, Green CE, Herin DV, Stotts AL, Moeller FG. High-dose naltrexone therapy for cocaine-alcohol dependence. The American journal on addictions. 2009;18(5):356–362.19874153
51 Schmitz JM, Stotts AL, Sayre SL, DeLaune KA, Grabowski J. Treatment of cocaine-alcohol dependence with naltrexone and relapse prevention therapy. The American journal on addictions. 2004;13(4):333–341.15370932
52 Schottenfeld RS, Chawarski MC, Cubells JF, George TP, Lappalainen J, Kosten TR. Randomized clinical trial of disulfiram for cocaine dependence or abuse during buprenorphine treatment. Drug and alcohol dependence. 2014;136:36–42.24462581
53 Schottenfeld RS, Chawarski MC, Pakes JR, Pantalon MV, Carroll KM, Kosten TR. Methadone versus buprenorphine with contingency management or performance feedback for cocaine and opioid dependence. The American journal of psychiatry. 2005;162(2):340–349.15677600
54 Schottenfeld RS, Pakes JR, Oliveto A, Ziedonis D, Kosten TR. Buprenorphine vs methadone maintenance treatment for concurrent opioid dependence and cocaine abuse. Archives of general psychiatry. 1997;54(8):713–720.9283506
55 Shoptaw S, Majewska MD, Wilkins J, Twitchell G, Yang X, Ling W. Participants receiving dehydroepiandrosterone during treatment for cocaine dependence show high rates of cocaine use in a placebo-controlled pilot study. Experimental and clinical psychopharmacology. 2004;12(2):126–135.15122957
56 Shoptaw S, Yang X, Rotheram-Fuller EJ, . Randomized placebo-controlled trial of baclofen for cocaine dependence: preliminary effects for individuals with chronic patterns of cocaine use. The Journal of clinical psychiatry. 2003;64(12):1440–1448.14728105
57 Shorter D, Lindsay JA, Kosten TR. The alpha-1 adrenergic antagonist doxazosin for treatment of cocaine dependence: A pilot study. Drug and alcohol dependence. 2013;131(1–2):66–70.23306096
58 Sofuoglu M, Carroll KM. Effects of galantamine on cocaine use in chronic cocaine users. The American journal on addictions. 2011;20(3):302–303.21477060
59 Sofuoglu M, Poling J, Babuscio T, . Carvedilol does not reduce cocaine use in methadone-maintained cocaine users. Journal of substance abuse treatment. 2017;73:63–69 28017186
60 Sofuoglu M, Poling J, Gonzalez G, Gonsai K, Oliveto A, Kosten TR. Progesterone effects on cocaine use in male cocaine users maintained on methadone: a randomized, double-blind, pilot study. Experimental and clinical psychopharmacology. 2007;15(5):453–460.17924779
61 Walsh SL, Middleton LS, Wong CJ, . Atomoxetine does not alter cocaine use in cocaine dependent individuals: double blind randomized trial. Drug and alcohol dependence. 2013;130(1–3):150–157.23200303
62 Winhusen TM, Kropp F, Lindblad R, . Multisite, randomized, double-blind, placebo-controlled pilot clinical trial to evaluate the efficacy of buspirone as a relapse-prevention treatment for cocaine dependence. The Journal of clinical psychiatry. 2014;75(7):757–764.24911028
63 George TP, Chawarski MC, Pakes J, Carroll KM, Kosten TR, Schottenfeld RS. Disulfiram versus placebo for cocaine dependence in buprenorphine-maintained subjects: a preliminary trial. Biological psychiatry. 2000;47(12):1080–1086.10862808
64 Petrakis IL, Carroll KM, Nich C, . Disulfiram treatment for cocaine dependence in methadone-maintained opioid addicts. Addiction (Abingdon, England). 2000;95(2):219–228.
65 Poling J, Oliveto A, Petry N, . Six-month trial of bupropion with contingency management for cocaine dependence in a methadone-maintained population. Archives of general psychiatry. 2006;63(2):219–228.16461866
66 Kampman KM, Pettinati H, Lynch KG, . A pilot trial of topiramate for the treatment of cocaine dependence. Drug and alcohol dependence. 2004;75(3):233–240.15283944
67 Kampman KM, Pettinati HM, Lynch KG, Spratt K, Wierzbicki MR, O’Brien CP. A double-blind, placebo-controlled trial of topiramate for the treatment of comorbid cocaine and alcohol dependence. Drug and alcohol dependence. 2013;133(1):94–99.23810644
68 Johnson BA, Ait-Daoud N, Wang X-Q, . Topiramate for the treatment of cocaine addiction: a randomized clinical trial. JAMA psychiatry. 2013;70(12):1338–1346.24132249
69 Nuijten M, Blanken P, van den Brink W, Hendriks V. Treatment of crack-cocaine dependence with topiramate: a randomized controlled feasibility trial in The Netherlands. Drug and alcohol dependence. 2014;138:177–184.24629631
70 Umbricht A, DeFulio A, Winstanley EL, . Topiramate for cocaine dependence during methadone maintenance treatment: a randomized controlled trial. Drug and alcohol dependence. 2014;140:92–100.24814607
71 Somoza EC, Winship D, Gorodetzky CW, . A multisite, double-blind, placebo-controlled clinical trial to evaluate the safety and efficacy of vigabatrin for treating cocaine dependence. JAMA psychiatry. 2013;70(6):630–637.23575810
72 Brodie JD, Case BG, Figueroa E, . Randomized, double-blind, placebo-controlled trial of vigabatrin for the treatment of cocaine dependence in Mexican parolees. The American journal of psychiatry. 2009;166(11):1269–1277.19651710
73 Kolar AF, Brown BS, Weddington WW, Haertzen CC, Michaelson BS, Jaffe JH. Treatment of cocaine dependence in methadone maintenance clients: a pilot study comparing the efficacy of desipramine and amantadine. The International journal of the addictions. 1992;27(7):849–868.1319961
74 Kosten TR, Rosen MI, Schottenfeld R, Ziedonis D. Buprenorphine for cocaine and opiate dependence. Psychopharmacology bulletin. 1992;28(1):15–19.1609037
75 Grabowski J, Rhoades H, Stotts A, . Agonist-like or antagonist-like treatment for cocaine dependence with methadone for heroin dependence: two double-blind randomized clinical trials. Neuropsychopharmacology: official publication of the American College of Neuropsychopharmacology. 2004;29(5):969–981.15039761
76 Margolin A, Avants SK, Kosten TR. Mazindol for relapse prevention to cocaine abuse in methadone-maintained patients. The American journal of drug and alcohol abuse. 1995;21(4):469–481.8561098
77 Margolin A ASKMRTKTR. High- and low-dose mazindol for cocaine dependence in methadone-maintained patients: A preliminary evaluation. Substance Abuse: Substance Abuse. 1997;18(3):125.
78 Shorter D, Nielsen DA, Huang W, Harding MJ, Hamon SC, Kosten TR. Pharmacogenetic randomized trial for cocaine abuse: disulfiram and alpha1A-adrenoceptor gene variation. European neuropsychopharmacology: the journal of the European College of Neuropsychopharmacology. 2013;23(11):1401–1407.23849431
79 Petry NM, Barry D, Alessi SM, Rounsaville BJ, Carroll KM. A randomized trial adapting contingency management targets based on initial abstinence status of cocaine-dependent patients. Journal of consulting and clinical psychology. 2012;80(2):276–285.22229758
80 Petry Nm ASMCKMHTMSRBSS. Contingency management treatments: Reinforcing abstinence versus adherence with goal-related activities. Journal of consulting and clinical psychology. 2006;74(3):592.16822115
81 Bhatt M, Zielinski L, Baker-Beal L, . Efficacy and safety of psychostimulants for amphetamine and methamphetamine use disorders: a systematic review and meta-analysis. Systematic reviews. 2016;5(1):189.27842569
82 Elkashef AM, Rawson RA, Anderson AL, . Bupropion for the treatment of methamphetamine dependence. Neuropsychopharmacology: official publication of the American College of Neuropsychopharmacology. 2008;33(5):1162–1170.17581531
83 Shoptaw S, Huber A, Peck J, . Randomized, placebo-controlled trial of sertraline and contingency management for the treatment of methamphetamine dependence. Drug and alcohol dependence. 2006;85(1):12–18.16621339
84 Colfax GN, Santos G-M, Das M, . Mirtazapine to reduce methamphetamine use: a randomized controlled trial. Archives of general psychiatry. 2011;68(11):1168–1175.22065532
85 Coffin PO, Santos G-M, Das M, . Aripiprazole for the treatment of methamphetamine dependence: a randomized, double-blind, placebo-controlled trial. Addiction (Abingdon, England). 2013;108(4):751–761.
86 Tiihonen J, Kuoppasalmi K, Fohr J, . A comparison of aripiprazole, methylphenidate, and placebo for amphetamine dependence. The American journal of psychiatry. 2007;164(1):160–162.17202560
87 Elkashef A, Kahn R, Yu E, . Topiramate for the treatment of methamphetamine addiction: a multi-center placebo-controlled trial. Addiction (Abingdon, England). 2012;107(7):1297–1306.
88 Heinzerling KG, Shoptaw S, Peck JA, . Randomized, placebo-controlled trial of baclofen and gabapentin for the treatment of methamphetamine dependence. Drug and alcohol dependence. 2006;85(3):177–184.16740370
89 Runarsdottir V, Hansdottir I, Tyrfingsson T, . Extended-Release Injectable Naltrexone (XR-NTX) With Intensive Psychosocial Therapy for Amphetamine-Dependent Persons Seeking Treatment: A Placebo-Controlled Trial. Journal of addiction medicine. 2017;11(3):197–204.28379861
90 Tiihonen J, Krupitsky E, Verbitskaya E, . Naltrexone implant for the treatment of polydrug dependence: a randomized controlled trial. The American journal of psychiatry. 2012;169(5):531–536.22764364
91 Coffin PO, Santos G-M, Hern J, . Extended-release naltrexone for methamphetamine dependence among men who have sex with men: a randomized placebo-controlled trial. Addiction (Abingdon, England). 2017.
92 Jayaram-Lindstrom N, Hammarberg A, Beck O, Franck J. Naltrexone for the treatment of amphetamine dependence: a randomized, placebo-controlled trial. The American journal of psychiatry. 2008;165(11):1442–1448.18765480
93 Brown ES, Gabrielson B. A randomized, double-blind, placebo-controlled trial of citicoline for bipolar and unipolar depression and methamphetamine dependence. Journal of affective disorders. 2012;143(1–3):257–260.22974472
94 Johnson BA, Ait-Daoud N, Elkashef AM, . A preliminary randomized, double-blind, placebo-controlled study of the safety and efficacy of ondansetron in the treatment of methamphetamine dependence. The international journal of neuropsychopharmacology. 2008;11(1):1–14.
95 Ling W, Shoptaw S, Hillhouse M, . Double-blind placebo-controlled evaluation of the PROMETATM protocol for methamphetamine dependence. Addiction (Abingdon, England). 2012;107(2):361–369.
96 Mancino Mj FZCMCCSOA. Randomized placebo controlled trial of sertraline and sertraline plus gabapentin in depressed, recently abstinent cocaine-dependent patients. Proceedings of the 71th Annual Scientific Meeting of the College on Problems of Drug Dependence;. 2009:94.
97 Ersche KD, Sahakian BJ. The neuropsychology of amphetamine and opiate dependence: implications for treatment. Neuropsychology review. 2007;17(3):317–336.17690986
98 Phillips KA, Epstein DH, Preston KL. Psychostimulant addiction treatment. Neuropharmacology. 2014;87:150–160.24727297
99 Dutra L, Stathopoulou G, Basden SL, Leyro TM, Powers MB, Otto MW. A meta-analytic review of psychosocial interventions for substance use disorders. Am J Psychiatry. 2008;165(2):179–187.18198270
100 Minozzi S, Saulle R, De Crescenzo F, Amato L. Psychosocial interventions for psychostimulant misuse. The Cochrane database of systematic reviews. 2016;9:CD011866.27684277
101 Moher D, Pham B, Lawson ML, Klassen TP. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health Technol Assess. 2003;7(41):1–90.
102 Schmitz JM, Stotts AL, Rhoades HM, Grabowski J. Naltrexone and relapse prevention treatment for cocaine-dependent patients. Addictive behaviors. 2001;26(2):167–180.11316375