# Summary and Discussion

In this systematic review, we examined 7 systematic reviews and 68 trials of a variety of pharmacotherapies for stimulant use disorder (46 for cocaine, 14 for amphetamine and/or methamphetamine), and found largely disappointing results. We found no strong, consistent evidence that any drug class was effective in increasing abstinence, reducing use, or improving study retention rates. As the summary of evidence table shows, a key issue was the absence of good quality evidence: we found insufficient to low strength evidence for all drug classes in amphetamine/methamphetamine use disorder and most of the drug classes in cocaine use disorder, suggesting that further research in these areas may alter conclusions. On the other hand, we also found some areas in which there was consistent evidence of no effect, or negative effect. For patients with cocaine use disorder, we found moderate to high strength evidence that antidepressants (specifically, SSRIs and TCAs) do not improve abstinence, use, or retention; moderate strength evidence that anticonvulsants do not improve use or retention; and low to moderate strength evidence that dopamine agonists do not improve abstinence or retention. We found moderate strength of evidence that SSRIs increase risk of study withdrawal due to adverse events and that disulfiram treatment was associated with lower retention than placebo.

A motivating factor behind this review was to find promising treatments for a devastating condition that has been historically difficult to treat with pharmacotherapy. We identified several potentially effective treatments, though the strength of evidence is low, underscoring the need for further research to strengthen conclusions. First, psychostimulants as a class, and the antidepressant bupropion, may improve abstinence in cocaine use disorder, though the same studies did not find an improvement in reducing cocaine use or treatment retention.^5^ The anticonvulsant topiramate may also be effective for continuous cocaine abstinence.^18,66,67^ Second, antidepressants and psychostimulants may be effective in patients with comorbid opioid use disorder.^11^ Third, topiramate has the potential to be beneficial in those with methamphetamine use disorder (based on the finding from 1 larger, well-done trial).^87^ Finally, antidepressants may decrease the risk of relapse in patients who have already achieved abstinence from cocaine.^41,96^ The use of pharmacotherapy for relapse prevention is an intriguing finding that warrants exploration. In subgroup analyses, we found that 2-or-more-week abstinence at baseline (confirmed by UA), or a negative UA at screening, were more likely to predict success.^19,46^ It is possible that those who are actively using stimulants are not engaged enough in treatment for pharmacotherapy to be effective. Retention rates varied widely across studies (24–97%), but overall low rates of retention could potentially affect the assessment of treatment effectiveness in the majority of studies (attrition was greater than 20% in 68% of the studies reporting retention rates). Unfortunately, pharmacotherapy itself does not appear to be effective in improving retention rates. Two areas of promise that are notable include those in which patients have already demonstrated engagement in treatment, or may have another rationale for ongoing engagement (as is the case for some patients with comorbid opiate use disorder, or tobacco use disorders). Perhaps the neurobiology of stimulant use disorders makes it more difficult for some to engage in treatment.^97^ Whether the negative results we found reflect the biology of disease or lack of efficacy of the pharmacological interventions is unclear.

As such, behavioral interventions (ie, contingency management, cognitive behavioral therapy, and community reinforcement approach) continue to be mainstays of treatment and management of stimulant use disorders.^98–100^ A systematic review by Minozzi et al found that any psychosocial treatment likely reduces drop-out rates, and may increase the period of abstinence (most of the studies reviewed involved contingency management in addition to treatment as usual).^100^ In our comparison of all included studies with and without CM, we found that pharmacotherapeutic effects were similar in studies with and without a CM co-intervention.

The decision to consider any treatment depends on the anticipated balance of benefits and harms. One might consider use of a medication with lower strength evidence of benefit if the potential for adverse effects was known to be low. In this body of evidence, however, data on harms was poorly reported, resulting in insufficient evidence to draw conclusions about harms for most of the drugs examined in this population. None of these drugs are FDA-approved for this indication. Most have been widely used for other indications for many years and many have well-known adverse effect profiles. There was moderate strength evidence that SSRIs may be associated with a higher rate of treatment withdrawal due to adverse effects, but very few studies reported on the nature and rate of severe adverse effects.

## Limitations

Our review has several limitations. The review scope was very broad and hence we had to rely on existing systematic reviews when available. We sought to minimize the downside of using existing reviews by only including those that met key quality criteria. We also updated reviews and included newer trials, or trials that had been missed in the original reviews. We had to choose a scheme for organizing results by drug class though this scheme could be debated. The definition of abstinence (2 or more weeks) is only a proxy for sustained (long-term) abstinence, but our Technical Expert Panel deemed it a reasonable and clinically important proxy that also reflects the reality of available trial literature. Finally, we limited our search to English language studies, though we believe the risk of missing literature that would have appreciably altered conclusions is low.^101^

There are also a number of limitations to this body of evidence. Many of the studies we included had methodologic flaws including poor outcome reporting, incomplete reporting of allocation methods, and small sample sizes. An anticipated limitation of the body of evidence which proved true was the high rate of attrition in the majority of studies. Because we were interested in treatment retention as an outcome, we did not consider attrition as a sole criterion for assessing study quality. An important and potentially amenable weakness in future studies was the marked variation in outcome reporting across trials. This precluded our ability to conduct meta-analyses in many cases because reported outcomes used various definitions and time points, preventing comparison to one another.

## Research Gaps/Future Research

Our review offers suggestions for future research. It is possible that the lack of significant findings was due to insufficient power to detect differences. Future studies need to be larger and assess clinically relevant and uniform outcomes, including reduction in use and defined periods of abstinence outcomes. Use of national or international clinical trial networks with standardized protocols may help address these limitations. There are a number of specific areas ripe for future work. In particular, we were surprised by the dearth of evidence in stimulant use disordered patients with co-occurring opioid use disorder. These patients are an important subgroup because they are a sizeable proportion of stimulant use disordered populations. The potentially promising areas listed above should also be examined further as these results need to be replicated in more studies and larger populations.

Our review corroborates and extends many prior reviews. To our knowledge, this is the first review to broadly summarize drug treatment effects across many different drug classes, and to include both cocaine and amphetamine/methamphetamine use disorder patients. We used outcome measures similar to existing SRs including reduction in stimulant use by proportion of negative UA, sustained abstinence, and retention in treatment.^5,12–16^ Unlike prior SRs, our review had international studies that increased external validity and generalizability to different settings.

## Conclusions

We found no strong, consistent evidence that any drug class was effective in increasing abstinence, reducing use, or improving retention rates. We found moderate to high strength evidence that antidepressants, disulfiram, and anticonvulsants (with the exception of topiramate) are unlikely to be effective in non-abstinent patients. There are several promising areas deserving of further research including the use of bupropion, topiramate, treatment of abstinent patients to prevent relapse, and treatment of patients with comorbid opioid use disorder.

Conclusions Table A Summary of the evidence on mental health pharmacotherapies for cocaine use disorder, stratified by drug class

Outcomes | N studies per outcome; ROB (N=combined participants) | Summary of findings by outcome | Strength of Evidence^a^ | Comments and rationale for strength of evidence rating
Antidepressants
All Antidepressants
Abstinence | 1 SR of 8 RCTs^16^ (N=942) 1 Low-ROB RCT^46^ (N=130) | No difference. One SR reported a combined 3+ week abstinence RR of 1.22 (95% CI 0.99 to 1.51), and an additional RCT found no difference between study groups. | Moderate | Inconsistency Trend toward benefit disappeared when restricted to studies using strict criteria for cocaine dependence.
Use | 1 SR of 4 RCTs^16^ (N=251) 1 Low-ROB RCT^46^ (N=130) 1 High-ROB RCT^17^ (N=24) | No difference. One SR reported a combined use of cocaine (self-reported or objective) RR of 1.05 (95% CI 0.91 to 1.21). Similar findings were reported in both more recent low-ROB and high-ROB RCTs. | Moderate | Indirectness (of outcome)
Relapse | 2 Low-ROB RCTs^41,96^ (N=133) | Favors antidepressants. Participants abstinent at baseline with 2 consecutive cocaine-positive UAs, combined RR 0.74 (95% CI 0.57 to 0.96). | Low | Small body of evidence Indirectness (of results to general population - participants had achieved abstinence prior to the outpatient phase). Lapse is defined as the first cocaine-positive UA, relapse is 2 consecutive cocaine-positive UAs.
Lapse | 2 Low-ROB RCTs^41,96^ (N=133) | Favors antidepressants. Abstinent at baseline participants with one cocainepositive UA, combined RR 0.79 (95% CI 0.62 to 1.00). | Low
Retention | 1 SR of 27 RCTs^16^ (N=2,417) 3 Low-ROB RCTs^41,46,96^ (N=263) | No difference. One SR reported RR 1.01 (95% CI 0.91 to 1.12). Three more recent low-ROB RCTs also found no difference in retention between groups. | High | Findings were similar in analyses limited to RCTs specifying DSM cocaine dependence criteria for inclusion.
Harms | 1 SR of 13 RCTs^16^ (N=1,396) 1 Low-ROB RCT^46^ (N=130) 1 High-ROB RCT^17^ (N=24) | No difference. One SR reported a combined withdrawal due to an adverse event RR of 1.39 (95% CI 0.91 to 2.12). Two more recent RCTs (1 low-ROB, 1 high-ROB) reported consistent findings. No difference. Two RCTs found no difference in severe adverse events by group. | Withdrawal due to AEs: Moderate Severe AEs: Low | Treatment withdrawal findings are from one low and one high RCT and a SR/meta-analysis of 37 RCTs. The SR included studies with any definition of cocaine dependence or abuse. Findings of SAEs are from a small body of evidence.
All Tricyclic Antidepressants
Abstinence | 1 SR of 5 RCTs^16^ (N=367) | No difference. 3+ week abstinence, combined RR 1.55 (95% CI 1.10 to 2.17). Limited to DSM criteria for cocaine dependence (3 studies, N= 234): combined RR 1.41, (95% CI 0.93 to 2.14). | Low | 4/5 studies are of desipramine.
Use | 1 SR of 2 RCTs^16^ (N=37) | No difference. Use of cocaine (selfreported or objective), combined RR 0.85 (95% CI 0.34 to 2.11) | Insufficient | Small body of evidence. Imprecise estimate. Indirectness (of outcome)
Retention | 1 SR of 15 RCTs^16^ (N=1,141) | No difference. Number of participants who did not complete the trial, combined RR 1.00 (95% CI 0.85 to 1.18) | High | Findings were similar in an analysis limited to RCTs specifying DSM cocaine dependence criteria for inclusion and in an analysis excluding high-ROB trials. 13/15 studies are of desipramine.
Harms | 1 SR of 5 RCTs^16^ (N=381) | No difference. Withdrawal due to an adverse event, combined RR 1.24 (95% CI 0.64 to 2.43) SAE: NA | Moderate No evidence: SAE | Findings were similar in analyses limited to RCTs specifying DSM cocaine dependence criteria for inclusion. Imprecise estimate. 4/5 studies are of desipramine.
Selective Serotonin Reuptake Inhibitors (SSRIs): Fluoxetine and Sertraline
Abstinence | NA | NA | No evidence | NA
Use | NA | NA | No evidence | NA
Relapse | 2 Low-ROB RCTs^41,96^ (N= 133) | Favors sertraline. Participants abstinent at baseline with 2 consecutive cocaine-positive UAs, combined RR 0.74 (95% CI 0.57 to 0.96). | Low | Small body of evidence Indirectness (of results to general population - participants had achieved abstinence prior to the outpatient phase). Lapse is defined as the first cocaine-positive UA, relapse is 2 consecutive cocaine-positive UAs.
Lapse | 2 Low-ROB RCTs^41,96^ (N= 133) | Favors sertraline. Abstinent at baseline participants with 1 cocaine-positive UA, combined RR 0.79 (95% CI 0.62 to 1.00). | Low
Retention | 1 SR of 7 RCTs^16^ (N=527) 2 Low-ROB RCTs^41,96^ (N=133) | No difference. The SR’s combined RR for participants not completing the trial was 0.99 (95% CI 0.70 to 1.71). No difference in 2 more recent RCTs. | Moderate | Inconsistent results. Findings favored placebo when excluding one outlier, and no difference was found when further excluding one high-ROB RCT. Indirectness (of population) - 2 more recent RCTs enrolled only patients who had achieved abstinence.
Harms | 1 SR of 3 RCTs^16^ (N=251) | Favors placebo. Withdrawal due to an adverse event, combined RR 3.55 (95% CI 1.11 to 11.34). SAE: NA | Low No evidence: SAE | Imprecise estimate Small body of evidence
Serotonin and Norepinephrine Reuptake Inhibitor (SNRI): Venlafaxine
Abstinence | 1 Low-ROB RCT^46^ (N=130) | No difference. One RCT found no difference in 3+ week abstinence between groups (P = 0.94). | Insufficient | One single-site study.
Use | 1 Low-ROB RCT^46^ (N=130) | No difference. One RCT found no difference in negative UAs between groups (P = 0.738). | Insufficient | One single-site study.
Retention | 1 Low-ROB RCT^46^ (N=130) | No difference. One RCT found no difference in retention between groups. | Insufficient | One single-site study.
Harms | 1 Low-ROB RCT^46^ (N=130) | No difference. One RCT found no difference in withdrawals due to adverse events by group. No difference. One RCT found no difference in severe AEs between groups. | Insufficient | One single-site study.
Atypical Antidepressant: Mirtazapine
Abstinence | NA | NA | No evidence | NA
Use | 1 High-ROB RCT^17^ (N=24) | No difference. One RCT found no difference in study period use between groups. | Insufficient | One very small underpowered study. Details regarding randomization and allocation concealment NR.
Retention | NA | NA | No evidence | NA
Harms | 1 High-ROB RCT^17^ (N=24) | No difference. One RCT found no difference in withdrawals due to AEs between groups (none). No difference. One RCT found no difference in severe AEs between groups (because there were none). | Insufficient | One very small underpowered study. Details regarding randomization and allocation concealment NR.
Aminoketone: Bupropion
Abstinence | 1 SR of 2 RCTs^5^ (N=176) | Favors bupropion. One SR reported a combined 2+ week abstinence RR of 1.63 (95% CI 1.03 to 2.59). | Low | Small body of evidence Imprecise estimates
Use | 1 SR of 2 RCTs^5^ (N=176) | No difference. Use of cocaine, combined SMD 0.24 (95% CI −0.06 to 0.54). | Low | Small body of evidence Imprecise estimates
Retention | 1 SR of 3 RCTs^16^ (N=325) | No difference. The SR’s combined RR for participants not completing the trial was 0.99 (95% CI 0.79 to 1.25). | Moderate | Inconsistent results
Harms | 1 SR of 1 RCT^5^ | No difference. Mean withdrawals due to AEs RD 0.00 (95% CI −0.05 to. 0.05) SAE: NA | Insufficient No evidence: SAE | Small body of evidence
Antipsychotics (All)
Abstinence | 1 SR of 3 RCTs^12^ (N=139) | No difference. One SR reported a combined 2+ week abstinence RR of 1.30 (95% CI 0.73 to 2.32). | Low | Small body of evidence Imprecise estimate
Use | 1 SR of 2 RCTs^12^ (N=150) 1 high-ROB RCT^39^ (N=18 opioid randomized, 41 enrolled opioid dependent participants) | No difference. | Low | Small body of evidence Methodologic limitations of studies Indirectness of population
Relapse | 1 high-ROB RCT^39^ (N=18 opioid randomized, 41 enrolled opioid dependent participants) | No difference. | Insufficient | Small, methodologically limited single trial. Indirectness (of results to general population - participants had achieved abstinence prior to the outpatient phase). Lapse is defined as the first cocaine-positive UA, relapse is 2 consecutive cocaine-positive UAs.
Lapse | 1 high-ROB RCT^39^ (N=18 opioid randomized, 41 enrolled opioid dependent participants) | No difference. | Insufficient
Retention | 1 SR of 8 RCTs^12^ (N=397) 1 high-ROB RCT^39^ (N=18 randomized, 41 enrolled opioid dependent participants) | Favors any antipsychotic. One SR reported RR 0.75 (95% CI 0.57 to 0.97). In addition, 1 high-ROB RCT of comorbid cocaine and opioid dependent methadone-maintained participants found no difference in retention between groups. | Moderate | Newer trial found no difference (indirectness of population).
Harms | 1 high-ROB RCT^39^ (N=18 randomized, 41 enrolled opioid dependent participants) | Withdrawals: No difference. SAE: NA | Insufficient No evidence: SAE | Small, methodologically limited single trial. Indirectness (of population)
First Generation Antipsychotics: Haloperidol
Abstinence | NA | NA | No evidence | NA
Use | NA | NA | No evidence | NA
Retention | 1 SR of 1 RCT^12^ (N=31) | No difference. One SR reported a RR for participants not completing the trial of 1.50 (95% CI 0.63 to 3.57). One head to head trial found no difference between haloperidol and olanzapine (N=31; RR 1.50 [95% CI 0.63 to 3.57]). | Insufficient | Findings are from a single study in a SR/meta-analysis of 14 RCTs.
Harms | NA | NA | No evidence | NA
Second Generation Antipsychotics: Aripiprazole, Olanzapine, Risperidone, Quetiapine
Abstinence | 1 SR of 3 RCTs^12^ (N=139) | No difference. Three studies in a SR found no difference between an atypical antipsychotic and placebo on sustained abstinence. | Low | Small body of evidence Imprecise estimate
Use | 1 SR of 1 RCT^12^ (N=31) 1 high-ROB RCT^39^ (N=18 randomized, 41 enrolled opioid dependent participants) | No difference. One RCT from one SR and 1 high-ROB RCT of opioid dependent participants found no difference between groups. | Insufficient | Small body of evidence Methodologic limitations of studies Indirectness of population
Relapse | 1 high-ROB RCT^39^ (N=18 randomized, 41 enrolled opioid dependent participants) | No difference. One high-ROB found no difference in relapse by group. | Insufficient | Small, methodologically limited single trial. Indirectness (of results to general population - participants had achieved abstinence prior to the outpatient phase). Lapse is defined as the first cocaine-positive UA, relapse is 2 consecutive cocaine-positive UAs.
Lapse | 1 high-ROB RCT^39^ (N=18 randomized, 41 enrolled opioid dependent participants) | No difference. One high-ROB found no difference in lapse by group. | Insufficient
Retention | 1 SR of 7 RCT^12^ (N=365) 1 high-ROB RCT^39^ (N=18 randomized, 41 enrolled opioid dependent participants) | No difference. Seven studies in one SR and 1 high-ROB RCT of comorbid cocaine and opioid dependent methadone-maintained participants found no benefit of atypical antipsychotics on study retention | Moderate | Newer trial found no difference (indirectness of population).
Harms | 1 high-ROB RCT^39^ (N=18 randomized, 41 enrolled opioid dependent participants) | No difference. One high-ROB RCT of comorbid cocaine and opioid dependent methadone-maintained participants found no difference in withdrawals due to AEs by group. SAE: NA | Insufficient No evidence: SAE | Small, methodologically limited single trial. Indirectness (of results to general population - participants had achieved abstinence prior to the outpatient phase).
Other Antipsychotics: Reserpine
Abstinence | NA | NA | No evidence | NA
Use | 1 SR of 1 RCT^12^ (N=119) | No difference. One study in the SR found a no difference in use between groups. | Insufficient | Small body of evidence. Imprecise estimate.
Retention | NA | NA | No evidence | NA
Harms | NA | NA | No evidence | NA
Psychostimulants: Dexamphetamine, Mazindol, Methamphetamine, Methylphenidate, Mixed Amphetamine Salts, Modafinil, Lisdexamphetamine, Selegiline
Abstinence | 1 SR of 14 studies^5^ (N=1,549) | Favors psychostimulants. One SR reported a combined 2+ week abstinence RR of 1.36 (95% CI 1.05 to 1.77). | Low | Large body of evidence and consistent results even after removing bupropion studies, but many trials were methodologically flawed. Findings from individual drugs favor dexamphetamine (small body of evidence) and mixed amphetamine salts (single study).
Use | 1 SR of 8 RCTs^5^ (N=526) | No difference. Use of cocaine, combined SMD 0.16 (95% CI −0.02 to 0.33). | Low | Trend toward small benefit, inconsistent results
Retention | 1 SR of 24 studies^5^ (N=2,205) | No difference. Number of participants who did not complete the trial, combined RR 1.00 (95% CI 0.93 to 1.06) | Moderate | Methodologic limitations of many included studies. Heterogeneous population.
Harms | Withdrawal: 1 SR of 19 RCTs^5^ (N=1,601) Serious AEs: 1 SR of 6 RCTs^5^ (N=444) | No difference. Number of participants who withdrew due to AEs, combined mean RD 0.00 (95% CI −0.01 to 0.01). No difference. Number of participants who reported severe AEs, combined mean RD −0.02 (95% CI −0.06 to 0.01). | Moderate | No bupropion studies are included in findings of SAEs..
Cognitive Enhancing Drugs: Memantine, Atomoxetine
Abstinence | 1 Low-ROB RCT^19^ (N=81) | No difference. Participants who did not achieve abstinence at baseline (N=45), there was no difference between groups in the achievement of sustained abstinence (3+ weeks). | Insufficient | Single small RCT with a 2-week placebo lead-in to encourage abstinence after randomization.
Use | 1 Low-ROB RCT^19^ (N=81) 1 Unclear-ROB RCT^61^ (N=50) | No difference. There was no difference in cocaine-negative UAs between groups. | Insufficient | Small body of evidence. Methodologic limitations of studies.
Relapse | 1 Low-ROB RCT^19^ (N=81) | No difference. Among participants who achieved abstinence at baseline (N=36), there was no difference between groups in relapse or time to relapse. | Insufficient | Small body of evidence. Indirectness (of results to general population - participants had achieved abstinence prior to the outpatient phase). Relapse is defined as 2 consecutive cocainepositive UAs.
Retention | 1 Low-ROB RCT^19^ (N=81) 1 Unclear-ROB RCT^61^ (N=50) | No difference. There was no difference in retention by group. | Insufficient | Small body of evidence. Methodologic limitations of studies.
Harms | 1 Low-ROB RCT^19^ (N=81) 1 Unclear-ROB RCT^61^ (N=50) | No difference. There was no difference in retention by group. No difference. 0 participants receiving memantine experienced a SAE compared to 2 who received placebo. | Insufficient | Small body of evidence. Methodologic limitations of studies.
Anxiolytics: Busiprone
Abstinence | 1 High-ROB RCT^62^ (N=62) | No difference. One RCT found no difference between groups in the mean number of days of (post-discharge) abstinence. | Insufficient | Small, methodologically limited single trial. Indirectness (of results to general population - participants had achieved abstinence prior to the outpatient phase). Lapse is defined as the first cocaine-positive UA, relapse is 2 consecutive cocaine-positive UAs.
Use | 1 High-ROB RCT^62^ (N=62) | NA | No evidence
Lapse | 1 High-ROB RCT^62^ (N=62) | No difference. One RCT found no difference between groups in number of days to lapse. | Insufficient
Retention | 1 High-ROB RCT^62^ (N=62) | No difference. One RCT reported high rates of retention (94% buspirone vs 93% placebo), but no difference between groups. | Insufficient
Withdrawal due to AE | 1 High-ROB RCT^62^ (N=62) | No difference. In 1 RCT there were no withdrawals due to AEs. | Insufficient
Severe AE | 1 High-ROB RCT^62^ (N=62) | Favors placebo. In 1 RCT there were 3 SAEs in participants receiving buspirone vs 0 receiving placebo. | Insufficient

Abbreviations: AE = Adverse event; CI = Confidence interval; DSM = Diagnostic and Statistical Manual of Mental Disorders; MD = mean difference; NR = no response; P = p-value; RCT = randomized control trial; RD = risk difference; RR = Risk ratio; ROB = Risk of bias; SAE = Severe adverse event; SMD = standard mean difference; SSRI = Selective Serotonin Reuptake Inhibitors; SR = Systematic review; UA = urinalysis

a The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:^10^

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. Insufficient = Any estimate of effect is very uncertain.

Conclusions Table B Summary of the evidence on pharmacotherapies that are prescribed for other stimulant use disorders in studies of patients with cocaine use disorder, stratified by drug

Outcome | N studies per outcome; ROB (N=combined participants) | Summary of findings by outcome | Strength of Evidence^a^ | Comments
Disulfiram
Abstinence | 2 RCTs^20,52^ (N=276) | No difference. Continuous abstinence disulfiram vs placebo, combined RR (95% CI) 1.22 (0.74 to 2.00) | Low | ROB unclear overall
Use | 4 RCTs^20,21,31,40^ (N=440) | No difference. Combined RR 0.95 (95% CI 0.64 to 1.39). The effect varied among studies, and statistical heterogeneity was highly significant (P <.00001). | Low | Heterogeneous findings among studies
Retention | 1 SR^15^ that included 2 RCTs (N=87): 1 unclear-ROB (N=20),^63^ 1 high-ROB^64^ (N=67) 5 low-ROB RCTs^20,21,31,40,52^ (N=617) | Favors placebo. Treatment retention was lower with disulfiram: RR 0.90 (95% CI 0.83 to 0.99). | Moderate | The combination of findings from all 7 studies (N=704) was statistically homogeneous (P=0.90)
Harms | 4 RCTs^21,31,40,52^ (N=548) | Withdrawals due to AE ranged from 0% to 5.9%, and included elevated liver enzymes and rash. Severe AEs not otherwise reported. | Low | ---
Naltrexone
Abstinence | 2 Low-ROB RCT^23,42^ 1 Unclear-ROB RCT^102^ (N=416) | No difference | Low | ---
Use | 1 Low-ROB RCT^51^ (N=80) | No difference | Insufficient
Retention | 3 Low RCTs^43,50,51^ 1 Unclear-ROB RCT^102^ | No difference | Low | ---
Harms | 1 low RCT^23^ (N=64) | No difference | Insufficient | ---
Acamprosate
Abstinence | --- | No evidence | ---
Use | 1 Low-ROB RCT^28^ (N=60) | No difference. % UA (-): 22% vs 23%, P=0.44 | Insufficient | Only one small RCT
Retention | 1 Low-ROB RCT^28^ (N=60) | No difference. 18/34 (53%) vs 18/26 (69%), P=ns. | Insufficient | Only one small RCT
Harms | --- | No evidence | ---
Varenicline
Abstinence | --- | No evidence | ---
Use | 2 Unclear-ROB RCTs^44,45^ (N=68) | Mixed findings | Insufficient
Retention | 2 Unclear-ROB RCTs^44,45^ (N=68) | No difference | Insufficient
Harms | 1 Unclear-ROB RCT^45^ (N=31) | No difference | Insufficient
Buprenorphine Plus Naloxone, 2 Doses
Abstinence | 1 Low-ROB RCT^34^ (N=302) | No difference | Insufficient
Use | 1 Low-ROB RCT^34^ (N=302) | Mixed findings. Significantly less use with Bup 16mg + naloxone 4mg vs placebo. No difference with lower dose | Insufficient
Retention | 1 Low-ROB RCT^34^ (N=302) | No difference | Insufficient
Harms | --- | No evidence | ---
Methadone vs Buprenorphine
Abstinence | 2 Low-ROB RCTs^53,54^ (N=278) | Mixed findings. Longer abstinence with methadone in 1 RCT; No difference in 1 RCT | Insufficient | Mixed findings
Use | 1 Low-ROB RCT^54^ (N=116) | Favors Methadone. Lower use with methadone vs buprenorphine (P<.05) | Insufficient
Retention | 2 Low-ROB RCTs^53,54^ (N=278) | Mixed findings. Better retention with methadone in 1 RCT; No difference in 1 RCT | Insufficient | Mixed findings
Harms | 1 Low-ROB RCT^53^ (N=162) | Elevated LFT in 1 subject | Insufficient

Abbreviations: AE = Adverse event; CI = Confidence interval; NR = no response; P = p-value; RCT = randomized control trial; RD = risk difference; RR = Risk ratio; ROB = Risk of bias; SAE = Severe adverse event; SMD = standard mean difference; SSRI = Selective Serotonin Reuptake Inhibitors; SR = Systematic review; UA = urinalysis

a The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:^10^

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. Insufficient = Any estimate of effect is very uncertain.

Conclusions Table C Summary of the evidence on anticonvulsants/muscle relaxants for cocaine use disorder, stratified by drug

Outcome | N studies per outcome; ROB (N=combined participants) | Summary of findings by outcome | Strength of Evidence^a^ | Comments
Carbamazepine, gabapentin, lamotrigine, phenytoin, tiagabine, topiramate, and vigabatrin (drugs combined in analysis)
Abstinence | 1 SR^14^ | NR | No evidence | These represent the combined results for all drug classes included in the SR.^14^ SOE was determined by the SR authors
Use | 1 SR of 9 RCTs^14^ (N=867) | No difference. Use of cocaine (selfreported or objective), combined RR 0.92 (95% CI 0.84 to 1.02)^14^ | Moderate^14^ | These represent the combined results for all drug classes included in the SR.^14^ SOE was determined by the SR authors
Retention | 1 SR that included 17 RCTs^14^ (N=1695) | No difference. RR 0.95 (95% CI 0.86 to 1.05)^14^ | Moderate^14^ | These represent the combined results for all drug classes included in the SR.^14^ SOE was determined by the SR authors
Topiramate
Abstinence | 1 Low-ROB RCT^18^ (N=60) 2 unclear-ROB RCTs^66,67^ | Favors topiramate (3 RCTs). Relapse prevention RCTs: Combined findings from 2 unclear-ROB RCTs^66,67^ (RR 2.56 [95% CI 1.39 to 4.73]) for 2 or more weeks of continuous abstinence | Low
Use | 1 Low-ROB RCT^18^ (N=60) | Favors topiramate. | Insufficient | Only one small trial
Retention | 5 RCTs: 1 High-ROB^69^; 2 Unclear-ROB^67,68^; 2 Low-ROB^18,70^ (N=605) | No difference. Combined RR 1.01 (95% CI: 0.93 to 1.10). | Moderate | Methodologic limitations of several trials.
Harms | 1 Low-ROB RCT^18^ (N=60) | No withdrawals occurred due to AE. No severe AEs occurred. | Insufficient | Only one small RCT
Vigabatrin
Abstinence | 1 Unclear-ROB RCT^71^ (N=186) 1 High-ROB RCT^72^ (N=103) | No difference. RR 2.35; 95% CI 0.92 to 5.98 | Low | Unclear effect overall due to mixed findings between studies; incomplete data was reported for the full trial period in both studies
Use | 1 Unclear-ROB RCT^71^ (N=186) 1 High-ROB RCT^72^ (N=103) | No difference. Total events: 76 (Treatment), 86 (Placebo). RR 0.88; 95% CI 0.69 to 1.13 | Low | Analysis from SR^14^
Retention | 1 Unclear-ROB RCT^71^ (N=186) 1 High-ROB RCT^72^ (N=103) | No difference. Total events: 98 (Treatment), 108 (placebo). RR 0.74; 95% CI 0.53 to 1.02. | Low
Harms | 1 Unclear-ROB RCT^71^ (N=186) | No difference. RR 0.97; 95% CI 0.88 to 1.08 | Insufficient
Baclofen
Abstinence | 2 Unclear-ROB RCTs^26,56^ (N=230) | No difference. | Low
Use | 2 Unclear-ROB RCTs^26,56^ (N=230) | No difference. | Low
Retention | 2 Unclear-ROB RCTs^26,56^ (N=230) | No difference. | Low
Withdrawal due to AE | 1 Unclear-ROB RCT^56^ (N=70) | No difference. | Insufficient
Severe AE | 2 Unclear-ROB RCTs^26,56^ (N=230) | No difference. | Low

Abbreviations: AE = Adverse Event; CI = Confidence Interval; RCT = Randomized control trial; ROB = Risk of Bias; RR = Risk Ratio; SR = Systematic review

a The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:^10^

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. Insufficient = Any estimate of effect is very uncertain.

Conclusions Table D Summary of the evidence on dopamine agonists for cocaine use disorder

Treatment; Outcomes | N studies per outcome (N=combined participants) | Summary of findings by outcome | Strength of Evidence | Comments
Amantadine, bromocriptine, L dopa/Carbidopa, pergolide, cabergoline hydergine, and pramipexole (drugs combined in analysis)
Abstinence | 1 SR of 11 RCTs^13^ (N=731) | No difference. At 6 weeks: RR 1.12 (95% CI 0.85 to 1.47) At 4 months: RR 1.1 (95% CI 0.61 to 1.98) | Low^13^ | Strength of evidence was determined by the SR authors^13^
Use | NR | NR | --- | Strength of evidence was determined by the SR authors^13^
Retention | 1 SR of 20 studies^13^ (N=1656) | No difference. RR 1.04 (95% CI 0.94 to 1.14) | Moderate^13^ | Strength of evidence was determined by the SR authors^13^
Harms | 1 SR of 7 studies^13^ (N=252) | SAEs and withdrawals due to AE NR. | No evidence^13^ | Strength of evidence was determined by the SR authors^13^

Abbreviations: AE = adverse event; CI = confidence interval; NR = Not reported; RR = Risk ratio; SAE = severe adverse event; SR = Systematic review

Conclusions Table E Summary of the evidence on mental health pharmacotherapies for comorbid cocaine and opioid use disorders, stratified by drug class

Outcome | N studies per outcome; ROB (N=combined participants) | Summary of findings by outcome | Strength of Evidence* | Comments
Antidepressants
Any Antidepressant
Abstinence | 1 SR of 3 RCTs^11^ (N=183) | Favors antidepressants. One SR reported a combined 3+ week abstinence RR of 1.82 (95% CI 1.19 to 2.78). | Low | Small body of evidence.
Use | 1 SR of 1 RCT^5^ (N=108) | No difference. One RCT reported no difference in use of cocaine. | Insufficient | Single study with methodologic limitations.
Retention | 1 SR of 10 RCTs^16^ (N=1,006) | Favors placebo. One SR reported a combined number of participants not completing the trial of RR 1.22 (95% CI 1.05 to 1.41). | Moderate | Findings were similar in analyses limited to RCTs specifying DSM cocaine dependence criteria for inclusion.
Harms | 1 SR of 5 RCTs^16^ (N=492) | Favors placebo. One SR reported a combined withdrawal due to an adverse event RR of 2.47 (95% CI 1.03 to 5.90). Severe AEs NR | Moderate | Body of evidence with methodologic flaws. Indirectness of population due to heterogeneity in inclusion criteria. Imprecision.
Tricyclic Antidepressants: Desipramine
Abstinence | 1 SR of 2 RCTs^11^ (N=78) | Favors desipramine. One SR reported a combined 3+ week abstinence RR of 2.73 (95% CI 1.20 to 6.21). | Insufficient | Small body of evidence. Imprecision.
Use | NA | NA | No evidence | NA
Retention | 1 SR of 6 RCTs^16^ (N=544) | Favors placebo. Number of participants who completed the trial, combined RR 0.86 (95% CI 0.74 to 0.99). | Moderate | Body of evidence with methodologic flaws. Indirectness of population due to heterogeneity in inclusion criteria.
Harms | 1 SR of 3 RCTs^16^ (N=157) | No difference. Withdrawal due to an adverse event, combined RR 1.66 (95% CI 0.35 to 7.96) Severe AEs NR | Low | Small body of evidence with methodologic flaws. Indirectness of population due to heterogeneity in inclusion criteria. Imprecision.
Selective Serotonin Reuptake Inhibitor: Fluoxetine
Abstinence | NA | NA | No evidence | NA
Use | NA | NA | No evidence | NA
Retention | 1 SR of 2 RCTs^16^ (N=207) | Favors placebo. One low-ROB RCT reported more dropouts in participants receiving fluoxetine. A second small high-ROB RCT found no difference between groups. | Insufficient (Low SOE of no benefit) | Small body of evidence with methodologic flaws. Indirectness of population due to heterogeneity in inclusion criteria. Imprecision.
Harms | 1 SR of 1 RCT^16^ (N=186) | Favors placebo. One low-ROB RCT reported more withdrawals due to AEs associated with fluoxetine. Severe AEs NR | Insufficient | Small body of evidence. Imprecision.
Aminoketone: Bupropion
Abstinence | 1 SR of 1 RCT^5^ (N=108) | Favors bupropion. One RCT reported more 3+ week abstinence in participants receiving bupropion. | Insufficient | Small body of evidence with methodologic flaws. Indirectness of population due to heterogeneity in inclusion criteria. Imprecision.
Use | 1 SR of 1 RCT^5^ (N=108) | No difference. One RCT reported no difference in use of cocaine. | Insufficient | Small body of evidence with methodologic flaws. Indirectness of population due to heterogeneity in inclusion criteria. Imprecision.
Retention | 1 SR of 2 RCTs^16^ (N=255) | No difference. Two RCTs in a SR reported no difference in participants completing the trial by group. | Low | Small body of evidence with methodologic flaws. Indirectness of population due to heterogeneity in inclusion criteria. Imprecision.
Harms | 1 SR of 1 RCT^16^ (N=149) | No difference. One RCT found no difference in withdrawals due to AEs by group. Severe AEs NR | Insufficient | Small body of evidence with methodologic flaws. Indirectness of population due to heterogeneity in inclusion criteria. Imprecision.
Antipsychotics: Aripiprazole, Risperidone
Abstinence | NA | NA | No evidence | NA
Use | 1 high-ROB RCT^39^ (N=18 opioid dependent participants) | No difference. One RCT found no difference in use by group. | Insufficient | Small, methodologically limited single trial. Indirectness (of results to general population - participants had achieved abstinence prior to the outpatient phase). Lapse is defined as the first cocaine-positive UA, relapse is 2 consecutive cocainepositive UAs.
Relapse | 1 high-ROB RCT^39^ (N=18 opioid dependent participants) | No difference. One RCT found no difference in relapse by group. | Insufficient
Lapse | 1 high-ROB RCT^39^ (N=18 opioid dependent participants) | No difference. One RCT found no difference in lapse by group. | Insufficient
Retention | 1 SR of 1 RCT^12^ (N=96) 1 high-ROB RCT39 (N=18 opioid dependent participants) | No difference. One high-ROB RCT and one RCT in an SR found no difference in retention between groups. | Low | Small body of evidence. Methodologic limitations of studies.
Harms | 1 high-ROB RCT^39^ (N=18 opioid dependent participants) | No difference. One found no difference in withdrawal due to AEs between groups. Severe AEs: NR | Insufficient | Small, methodologically limited single trial. Indirectness of population.
Psychostimulants: Dexamphetamine, Mazindol
Abstinence | 1 SR of 2 RCTs^11^ (N=131) | Mixed Findings. 3+ week abstinence, RR 1.58 (95% CI 0.63 to 4.00). Findings favor dexamphetamine, but not mazindol. | Insufficient | Small body of evidence with methodologic flaws. Imprecision.
Use | 1 SR of 3 RCTs^11^ (N=115) | Favors psychostimulants. Use of cocaine, SMD 0.35 (95% CI −0.05 to 0.74). | Low | Small body of evidence with methodologic flaws. Imprecision.
Retention | 1 SR of 3 RCTs^5^ (N=297) | No difference. Three RCTs found no difference in the number of participants who did not complete the trial. | Low | Small body of evidence with methodologic flaws. Imprecision.
Harms | NA | NA | No evidence | NA

Abbreviations: AE = adverse event; CI = confidence interval; MD = mean difference; NR = Not reported; RCT = randomized control trial; RD = risk difference; ROB = Risk of bias; RR= risk ratio; SAE = sever adverse event; SMD = standard mean difference; SR = Systematic review; SOE = strength of evidence

a The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:^10^

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. Insufficient = Any estimate of effect is very uncertain.

Conclusions Table F Summary of the evidence on the use of pharmacotherapies prescribed for other stimulant use disorders in studies of patients with comorbid cocaine and opioid use disorders, stratified by drug

Outcome | N studies per outcome; ROB (N=combined participants) | Summary of findings by outcome | Strengt of Evidence^a^ | Comments
Disulfiram
Abstinence | 1 Low-ROB RCT^52^ (N=177) 1 Unclear-ROB RCT^63^ (N=20) | No difference. RR 0.89 (95% CI 0.53 to 1.48) | Low | P-value for statistical heterogeneity = 0.73
Use | 3 Low-ROB RCTs^21,31,40^ (N=332) | Mixed findings | Insufficient | Significant statistical heterogeneity among studies (P<.00001)
Retention | 4 Low-ROB RCTs^21,31,40,52^ (N=341) 1 Unclear-ROB RCT^63^ (N=20) 1 High-ROB RCT^64^ (N=67) | Favors placebo. RR 0.87 (95% CI 0.77 to 0.98) | Moderate | P-value for statistical heterogeneity = 0.94
Harms | --- | No evidence | ---
Varenicline
Abstinence | --- | No evidence | ---
Use | 2 Unclear-ROB RCTs^44,45^ (N=68) | Mixed findings | Insufficient
Retention | 2 Unclear-ROB RCTs^44,45^ (N=68) | No difference | Insufficient
Harms | 1 Unclear-ROB RCT^45^ (N=31) | No difference | Insufficient
Opioid Agonists
Buprenorphine Plus Naloxone
Abstinence | 1 Low-ROB RCT^34^ (N=302) | No difference | Insufficient
Use | 1 Low-ROB RCT^34^ (N=302) | Mixed findings | Insufficient | Varies with dose
Retention | 1 Low-ROB RCT^34^ (N=302) | No difference | Insufficient
Harms | --- | No evidence | Insufficient
Methadone vs Buprenorphine
Abstinence | 2 Low-ROB RCTs^53,54^ (N=278) | Mixed findings | Insufficient
Use | --- | No evidence
Retention | 2 Low-ROB RCTs^53,54^ (N=278) | Mixed findings. | Insufficient
Harms | --- | No evidence | ---

Abbreviations: AE = Adverse event; CI = Confidence interval; CM = contingency management; MA = meta-analysis; OR = odds ratio; P = p-value; RCT = randomized control trial; ROB = Risk of bias; SR = Systematic review; UA = urinalysis; wk = week

a The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:^10^

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. Insufficient = Any estimate of effect is very uncertain.

Conclusions Table G Summary of the evidence on mental health pharmacotherapies for amphetamine/methamphetamine use disorder

Treatment comparison | N studies per outcome; ROB (N=combined participants) | Summary of findings by outcome | Strength of Evidence^a^ | Comments
Antidepressants
All Antidepressants
Abstinence | 1 SR of 3 RCTs^81^ (N=361) 1 Unclear-ROB RCT^83^ (N=229) | No difference. One SR reported and one additional unclear-ROB RCT reported similar findings. | Moderate | Body of evidence with methodologic flaws. Consistent findings across studies.
Use | 1 SR of 3 RCTs^81^ (N=122) 1 Unclear-ROB RCT^82^ (N=151) 1 High-ROB RCT^84^ (N=60) | Mixed findings. One SR included 2 RCTs that found no difference in negative UAs, and one small trial (N=19) that favored placebo. One additional RCT found no differences in week 12 negative UAs and rate of reduction, but a modest trend towards improvement favoring bupropion (P = 0.09). One small trial of MSM found that participants receiving mirtazapine had more negative UAs, with a larger increase in the number of negative UA participants. | Insufficient | Body of evidence with methodologic flaws. Indirectness of population.
Retention | 1 SR of 4 RCTs^81^ (N=391) 2 Unclear-ROB RCTs^82,83^ (N=380) 1 High-ROB RCT^84^ (N=60) | No difference. One SR reported a combined number of participants not completing the trial of OR 1.10 (95% CI 0.73 to 1.67). Two additional RCTs also found no difference in retention, and one RCT reported findings favoring placebo. | Moderate | Body of evidence with methodologic flaws. Indirectness of population. Consistent findings across studies.
Harms | 1 Unclear-ROB RCT^82^(N=151) 1 High-ROB RCT^84^ (N=60) | Withdrawal due to AEs: NA No difference. Two RCTs found no difference between groups in reported severe AEs. | No evidence: Withdrawal due to AEs. Low: SAEs | Small body of evidence with methodologic flaws.
Aminoketone: Bupropion
Abstinence | 1 SR of 3 RCTs^81^ (N=361) | No difference. One SR reported combined abstinence OR of 1.12 (95% CI 0.54 to 2.33). | Low | Small body of evidence with methodologic flaws. Imprecision.
Use | 1 SR of 3 RCTs^81^ (N=122) 1 Unclear-ROB RCT^82^ (N=151) | No difference. One SR included 2 RCTs that found no difference in negative UAs, and one small trial (N=19) that favored placebo. In addition, one RCT found no differences in week-12 negative UAs and rate of reduction, but a modest trend towards improvement favoring bupropion (P = 0.09). | Low | Body of evidence with methodologic flaws.
Retention | 1 SR of 4 RCTs^81^ (N=391) 1 Unclear-ROB RCT^82^ (N=151) | No difference. One SR reported a combined number of participants not completing the trial of OR 1.10 (95% CI 0.73 to 1.67). One additional RCT also found no difference in retention. | Moderate | Body of evidence with methodologic flaws.
Harms | 1 Unclear-ROB RCT^82^ (N=151) | No difference. There was no difference between groups in reported severe AEs. Withdrawal due to AEs: NA | No evidence: Withdrawal due to AEs Insufficient: SAEs | Single multi-site study with methodological flaws. Imprecision.
Atypical Antidepressant: Mirtazapine
Abstinence | NA | NA | No evidence | NA
Use | 1 High-ROB RCT^84^ (N=60) All participants: Men who have sex with men | Favors mirtazapine. At the end of the study participants receiving mirtazapine had more negative UAs, with a larger increase in the number negative UA participants. | Insufficient | Single study with methodological flaws. Indirectness of study population. Imprecision.
Retention | 1 High-ROB RCT^84^ (N=60) All participants: Men who have sex with men | No difference. There was no difference between study groups. | Insufficient | Single study with methodological flaws. Indirectness of study population. Imprecision.
Harms | 1 High-ROB RCT^84^ (N=60) All participants: Men who have sex with men | No difference. There was no difference in SAEs between study groups. Withdrawal due to AEs: NA | No evidence: Withdrawal due to AEs Insufficient: SAEs | Single study with methodological flaws. Indirectness of study population. Imprecision.
Selective Serotonin Reuptake Inhibitor: Sertraline
Abstinence | 1 Unclear-ROB RCT^83^ (N=229) | No difference. For participants receiving sertraline with or without CM vs placebo with or without CM, there was a strong trend favoring placebo (P=0.052). | Insufficient | Single multi-site study with methodological flaws. Imprecision.
Use | NA | NA | No evidence | NA
Retention | 1 Unclear-ROB RCT^83^ (N=229) | Favors placebo. Participants receiving sertraline were retained for significantly less time than those receiving placebo. When collapsed, fewer participants receiving sertraline with or without CM were retained. | Insufficient | Single multi-site study with methodological flaws. Imprecision.
Harms | NA | NA | No evidence | NA
Atypical Antipsychotics: Aripiprazole
Abstinence | 1 Unclear-ROB RCT^85^ (N=90) | No difference. One study found no difference in 2+ week abstinence. | Insufficient | Single study with methodological flaws. Imprecision.
Use | 1 Unclear-ROB RCT^85^ (N=90) 1 High-ROB RCT^86^ (N=53) | No difference. Neither study found a positive effect of aripiprazole on reducing methamphetamine use (one study significantly favored placebo). | Low | Small body of evidence with methodological flaws. Imprecision.
Retention | 1 High-ROB RCT^86^ (N=53) | No difference. No difference in the number of participants who did not complete the trial. | Insufficient | Single study with methodological flaws that was ended early due to unfavorable interim results. Imprecision
Harms | Withdrawal due to AEs: 1 Unclear-ROB RCT^85^ (N=90) 1 High-ROB RCT^86^ (N=53) Severe AEs: 1 High-ROB RCT^86^ (N=53) | Favors placebo. One unclear-ROB study found significantly more withdrawals due to AEs than placebo. A second small high-ROB study found no difference. No difference. One high-ROB found no difference in severe AEs. | Insufficient | Small body of evidence with methodological flaws.
Psychostimulants: Modafinil, Dexamphetamine, Methylphenidate
Abstinence | 1 SR of 2 RCTs^81^ (N=281) | No difference. One SR reported combined abstinence OR of 0.86 (95% CI 0.46 to 1.61). | Low | Small body of evidence with methodological flaws.
Use | 1 SR of 9 RCTs^81^ (N=551) | Mixed Findings. Six of 9 RCTs in a SR reported no difference in negative UAs. Three of 4 RCTs (N=278; 1 low, 3 high-ROB) reported a positive effect of methylphenidate on methamphetamine use. | Insufficient | Body of evidence with methodologic flaws. Findings in favor of methylphenidate (low SOE), but not modafinil and dexamphetamine.
Retention | 1 SR of 11 RCTs^81^ (N=1,027) | No difference. Number of participants who did not complete the trial, combined OR 1.11 (95% CI 0.86 to 1.44). | Low | Body of evidence with methodologic flaws. Participants receiving bupropion are included in the combined OR. Findings were similar for bupropion were similar.

Abbreviations: AE = adverse event; CI = confidence interval; MD = mean difference; NR = Not reported; OR = Odds ratio; RCT = randomized control trial; RD = risk difference; ROB = Risk of bias; RR= risk ratio; SAE = severe adverse event; SMD = standard mean difference; SR = Systematic review; SOE = strength of evidence

a The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:^10^

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. Insufficient = Any estimate of effect is very uncertain.

Conclusions Table H Summary of the evidence on anticonvulsants/muscle relaxants for amphetamine/methamphetamine use disorder

Treatment; Outcomes | N studies per outcome; ROB (N=combined participants) | Summary of findings | Strength of Evidence^a^ | Comments
Topiramate
Abstinence | 1 Low-ROB RCT^87^ (N=140) | NR | No evidence
Use | 1 Low-ROB RCT^87^ (N=140) | Favors topiramate. Use was significantly lower in treatment vs placebo | Low
Retention | 1 Low-ROB RCT^87^ (N=140) | No difference. | Low
Withdrawal due to AE | 1 Low-ROB RCT^87^ (N=140) | No difference. | Low
Severe AE | 1 Low-ROB RCT^87^ (N=140) | NR | No evidence
Baclofen vs Gabapentin
Abstinence | 1 Low-ROB RCT^88^ (N=88) | No difference. | Insufficient | Only one study
Use | 1 Low-ROB RCT^88^ (N=88) | No difference. | Insufficient | Only one study
Retention | 1 Low-ROB RCT^88^ (N=88) | No difference. | Insufficient | Only one study
Withdrawal due to AE | 1 Low-ROB RCT^88^ (N=88) | No difference. | Insufficient | Only one study
Severe AE | 1 Low-ROB RCT^88^ (N=88) | NR | No evidence

Abbreviations: AE = Adverse Event; NR = not reported; P = P-value; RCT = Randomized control trial; ROB = Risk of Bias

a The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:^10^

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. Insufficient = Any estimate of effect is very uncertain.

Conclusions Table I Summary of the evidence on pharmacotherapies used for other stimulant use disorders in studies of patients with amphetamine/methamphetamine use disorder

Treatment; Outcomes | N studies per outcome; ROB (N=combined participants) | Summary of findings by outcome | Strength of Evidence^a^ | Comments
Opioid Antagonists
Naltrexone
Abstinence | 1 unclear-ROB RCT^91^ (N=100) | No difference. | Insufficient | 1 small RCT involving MSM participants limiting applicability to general population
Use | 1 low-ROB RCTs^92^ (N=80) 3 unclear-ROB RCTs^89^-^91^ (N= 300) | Mixed findings. No consistent evidence of effect | Insufficient | Inconsistent results and methodological limitations. Higher rate of negative UA in 1 low-ROB study, but no difference in 3 unclear-ROB studies.
Retention | 1 low-ROB RCTs^92^ and 3 unclear-ROB RCTs were included in MA^89^-^91^ (N= 380) | No difference. Treatment retention naltrexone vs placebo: RR =1.11, 95% CI .88–1.41 I2=61% | Low | Studies reported inconsistent results and risk of bias
Harms | 1 low-ROB RCTs^92^ (N=80) 3 unclear-ROB RCTs^89^-^91^ (N= 300) | No difference. WD due to AE Only 1 of the 4 studies reported severe AE’s (3)^91^ | Moderate | Studies had low and unclear-ROB.

Abbreviations: AE = Adverse event; CI = Confidence interval; MSM = men who have sex with men; RCT = randomized control trial; ROB = Risk of bias; RR = risk ratio; SR = Systematic review; UA = urinalysis; wk = week

a The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:^10^

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidenc in the estimate of effect and is likely to change the estimate. Insufficient = Any estimate of effect is very uncertain.

Conclusions Table J Summary of the evidence on pharmacotherapies in patients with comorbid amphetamine/methamphetamine and opioid use disorders

Treatment; Outcomes | N studies per outcome; ROB (N=combined participants) | Summary of findings by outcome | Strength of Evidence^a^ | Comments
Opioid Antagonists
Naltrexone
Abstinence | 0 RCTs | No studies | No evidence | There were no studies that reported abstinence outcomes in opioid use disorder populations.
Use | 1 unclear-ROB RCTs^90^ (N=100) | No difference. | Insufficient | Only 1 study limited by unclear-ROB and imprecision due to small sample size.
Retention | 1 unclear-ROB RCTs^90^ (N=100) | Favors naltrexone. The study found increased retention in the treatment group at 10 weeks. | Insufficient | Only 1 study limited by unclear-ROB and imprecision due to small sample size.
Harms | 1 unclear-ROB RCTs^90^ (N=100) | The study reported no AEs and no withdrawals due to AE. | Insufficient | Only 1 study limited by unclear-ROB and imprecision due to small sample size.

Abbreviations: AE = Adverse event; RCT = randomized control trial; ROB = Risk of bias; SR = Systematic review; UA = urinalysis

a The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:^10^

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. Insufficient = Any estimate of effect is very uncertain.