# Methods

## Topic Development

The research questions for this systematic review were nominated by the Office of Mental Health and the Seattle and Philadelphia Centers for Substance Abuse Treatment & Education (CESATE), and were developed after a topic refinement process that included a preliminary review of published peer-reviewed literature, and consultation with internal partners, investigators, and stakeholders. The Key Questions are as follows:

- KQ1: What are the benefits and harms of pharmacotherapy for cocaine use disorder?
- KQ2: Are there known subpopulations for whom different forms of pharmacotherapy are most/least effective for cocaine use disorder?
- KQ3: What are the benefits and harms of pharmacotherapy for amphetamine/methamphetamine use disorder?
- KQ4: Are there known subpopulations for whom different forms of pharmacotherapy are most/least effective for amphetamine/methamphetamine use disorder?

Our approach was guided by a conceptual framework developed in consultation with our operational partners (see Figure 1). A protocol describing the review plan was posted to a publicly accessible website before the study was initiated (PROSPERO registration number CRD42018085667).

Figure 1 Analytic Framework

* Primary outcome

## Search Strategy

Search strategies were developed in consultation with a research librarian, and were peer reviewed by a second research librarian using the instrument for Peer Review of Search Strategies (PRESS; see Appendix A for the search strategy). We searched Ovid MEDLINE, OvidPsycINFO, and Ovid EBM Reviews Cochrane Database of Systematic Reviews (CDSR, DARE, HTA, and Cochrane CENTRAL). We searched all available years of publication from database inception (1946 for Ovid MEDLINE®) through November 2017. We reviewed the bibliographies of relevant articles and contacted experts to identify additional studies.

To identify in-progress or unpublished studies, we searched ClinicalTrials.gov, OpenTrials, and the World Health Organization (WHO) International Clinical Trials Registry Platform (ICTRP).

## Study Selection

The criteria for population, interventions, comparators, outcomes, timing, and setting (PICOTS) that apply to each key question were developed in collaboration with our operational partners and Technical Expert Panel (TEP; see Appendix B), and are specified in Table 1.

We included studies that directly compared pharmacological interventions against each other, placebo, usual care, or psychotherapy in adults with cocaine or amphetamine/methamphetamine use disorders. We excluded studies and comparisons examining patients with comorbid psychotic spectrum or bipolar disorders. We examined only randomized controlled trials. We excluded studies that did not perform drug urinalysis (UA) at least once per week. For outcomes related to abstinence and use, we excluded studies that relied on self-reported drug use, with the exception of findings from previous systematic reviews. We used a “best evidence” approach to guide additional study design criteria depending on the question under consideration and the literature available.^8^ Appendix C contains the detailed criteria we used for determining study eligibility.

Given the broad scope of this review, we summarized data from existing good-quality systematic reviews, when available, to address each question and outcome of interest, and added individual studies meeting inclusion criteria that were published after the end of the search date of the included review, or were not included in a prior systematic review.

Using pre-specified inclusion criteria, 2 independent reviewers evaluated titles and abstracts for 18.6% of the search yield to ensure reliability between reviewers. A single reviewer evaluated the remainder. Titles and abstracts were screened using Abstrackr,^9^ a semi-automated, web-based screening tool. We reviewed funded research for inclusion according to the same pre-specified inclusion criteria. Two investigators independently reviewed the full text of all potentially relevant articles for inclusion. All discordant results were resolved through consensus or consultation with a third reviewer.

Table 1 PICOTS by Key Question

Key Question | KQ1: What are the benefits and harms of pharmacotherapy for cocaine use disorder (alone, or as an adjunct or follow-up to psychosocial treatment)? | KQ2: Are there subpopulations for whom different forms of pharmacotherapy are most/least effective for cocaine use disorder? | KQ3: What are the benefits and harms of pharmacotherapy for amphetamine/methamphetamine use disorder (alone, or as an adjunct or follow-up to psychosocial treatment)? | KQ4: Are there subpopulations for whom different forms of pharmacotherapy are most/least effective for amphetamine/methamphetamine use disorder?
Population | Included: Non-pregnant adults with cocaine use disorder. Excluded: subjects with psychotic spectrum disorder, bipolar disorder. | Subpopulations may include:; - Demographic factors; - Housing status; - Severity; - Comorbid mental and substance use disorders (eg, HIV, mood and anxiety disorders, ADHD, alcohol use, opioid use/methadone maintained); - Other clinical conditions | Included: Non-pregnant adults with amphetamine/methamphetamine use disorder. Excluded: subjects with psychotic spectrum disorder, bipolar disorder. | Subpopulations may include:; - Demographic factors; - Housing status; - Severity; - Comorbid mental and substance use disorders (eg HIV, mood and anxiety disorders, ADHD, alcohol use, opioid use/methadone maintained); - Other clinical conditions
Intervention | Included: Pharmacotherapies identified as a potential treatment for cocaine use disorder (common adjuncts may be med management; interpersonal therapy; contingency management (or motivational incentives); CBT (including matrix therapy, relapse prevention) Excluded: treatment for temporary psychosis associated with stimulant overdose. | | Included: Pharmacotherapies identified as a potential treatment for amphetamine/methamphetamine use disorder (common adjuncts may be med management; interpersonal therapy; contingency management (or motivational incentives); CBT (including matrix therapy, relapse prevention) Excluded: treatment for temporary psychosis associated with stimulant overdose.
Comparators | Usual care, placebo, or other interventions (control groups should receive the same adjunctive treatments) | | Usual care, placebo, or other interventions (control groups should receive the same adjunctive treatments)
Outcomes | - Intermediate/Behavioral outcomes; - Abstinence (UA only. Self-report only in addition to UA) Also of interest when available: Longest Duration of Abstinence (LDA), and whether patients reach at least 3 Consecutive Weeks (21 or more days) of abstinence.; - Cocaine use (quantitative urine levels); - Retention in treatment; - Health and other outcomes; - Morbidity/mortality; - Quality of Life; - Legal/employment outcomes; - Harms; - Study withdrawal due to AE, and severe AE (as reported in the trials) | | - Intermediate/Behavioral outcomes; - Abstinence (UA only. Self-report only in addition to UA) Also of interest when available: Longest Duration of Abstinence (LDA), and whether patients reach at least 3 Consecutive Weeks (21 or more days) of abstinence.; - Cocaine use (quantitative urine levels); - Retention in treatment; - Health and other outcome; - Morbidity/mortality; - Quality of Life; - Legal/employment outcomes; - Harms; - Study withdrawal due to AE, and severe AE (as reported in the trials)
Timing | - Minimum study duration (including follow-up) 4 weeks
Settings | - Outpatient; - Inpatient; - Incarceration/detention centers, correctional facilities | | - Outpatient; - Inpatient; - Incarceration/detention centers, correctional facilities
Study design | - Randomized controlled trials.; - Systematic reviews | | - Randomized controlled trials; - Systematic reviews

Abbreviations: ADHD = Attention Deficit Hyperactivity Disorder; AE = Adverse event; KQ = key question; LDA = longest duration of abstinence; CBT = Cognitive Behavioral Therapy; HIV = human immunodeficiency virus; UA = urinalysis

## Data Abstraction

Data from studies meeting inclusion criteria were abstracted into a customized database by one reviewer and confirmed by a second. From each primary study identified in our search, we abstracted the following where available: study setting; subpopulations; inclusion and exclusion criteria; demographic information; addiction severity at baseline; details of active and comparator arms including concomitant treatments, number of UAs per week, dose, and duration; outcome data including abstinence, use, retention, and harms including withdrawals from treatment and severe adverse events. To combine data from studies included in previous systematic reviews with data from more recent trials identified in our search, in most cases we transferred outcome data presented in forest plots of meta-analyses conducted by the previous systematic reviews, rather than directly from the primary studies. In cases where a systematic review did not analyze continuous abstinence, we examined the primary studies identified by the systematic review to abstract data on continuous abstinence.

## Quality Assessment

Two reviewers independently assessed the risk of bias of each study (Appendix D). Disagreements were resolved through discussion. To assess the risk of bias of trials we used a tool developed by the Cochrane Collaboration.^1^ Each trial was given an overall summary assessment of low, high, or unclear risk of bias. In cases where we analyzed data from individual trials that were included in a previous systematic review, we summarized the risk of bias based on the study quality assessments previously made by the authors of the systematic review.

## Data Synthesis

We qualitatively synthesized the evidence for each key question, and conducted meta-analyses when combinable outcomes were reported among studies of the same drug or drug class. For studies in which an outcome of interest was collected but not completely reported, we contacted the authors to request the data elements needed for meta-analysis. We used RevMan 5.3^2^ to estimate relative risk across studies, under the assumption of random effects. For key questions 1 and 3, we provide findings across all studies, as well as for studies limited to individuals with comorbid opioid use disorder. For studies which did not fall under any of the principal drug categories, and for which there was only 1 RCT per pharmacotherapy, we described them qualitatively in brief in KQ 1 and 3 under “other pharmacotherapies.” We were aware of the National Institute on Drug Abuse (NIDA)’s Cocaine Rapid Efficacy Screening Trial (CREST) program that studied a broad a variety of drugs in single, small trials, and those that met our inclusion criteria are described in these sections. As there was only 1 study of each drug, we did not grade their strength of evidence or include them in summary tables.

## Rating the Body of Evidence

We assessed the overall strength of evidence for outcomes using a method developed for the Agency for Healthcare Research and Quality’s (AHRQ) Evidence-based Practice Centers (EPCs).^10^ The AHRQ EPC method considers study limitations, directness, consistency, precision, and reporting bias to classify the strength of evidence for individual outcomes independently for randomized controlled trials (RCTs). Ratings were based on the following criteria:

- High = Very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies, the findings are stable, and another study would not change the conclusions.
- Moderate = Moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies and the findings are likely to be stable, but some doubt remains.
- Low = Limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). Additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient = No evidence, unable to estimate an effect, or no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## Literature Flow

Our search of electronic databases, bibliographies, and other sources resulted in a total of 5,564 studies. After title and abstract review, 354 met inclusion criteria. Upon full-text review, we included a total of 8 systematic reviews and 61 RCTs. Several RCTs and systematic reviews provide data for more than one key question. See Figure 2 for the literature flow. Table 2 lists the numbers of previous systematic reviews and more recent trials identified in our search according to drug and drug class, stratified by substance use disorder.

Figure 2 Literature Flow Diagram

*Several studies addressed more than one key question.

Table 2 Number of systematic reviews and primary trials by drug and drug class, stratified by substance use disorder

SRs | Trials not in previous SRs | Drug category | Drug
Cocaine use disorder
3 | 4 | Antidepressants | Bupropion, mirtazapine, sertraline, venlafaxine
1 | --- | Antipsychotics | Aripiprazole, haloperidol, lamotrigine, olanzapine, quetiapine, reserpine, risperidone
--- | 1 | Antipsychotics | Aripiprazole
--- | 1 | Anxiolytics | Buspirone
--- | 2 | Cognitive enhancement | Memantine
1 | --- | Dopamine agonists | ---
1 | 14 | Medications for other SUDs | Acamprosate (1 RCT) Disulfiram (6 RCTs, 1 SR) Naltrexone (6 RCTs) Varenicline (2 RCTs)
--- | 2 | Muscle relaxants/anticonvulsants | Baclofen
1 | 1 | Muscle relaxants/anticonvulsants | Topiramate
--- | 19 | Other pharmacotherapies | 1 trial of each: Amlodipine, carvedilol, celecoxib, citicoline, D-Cycloserine, Dehydroepiandrosterone/DHEA, Doxazosin, Galantaeine, Magnesium L-aspartatehydrochloride, Mecamylamine, metyrapone + oxazepam, mixed amphetamine salts + topiramate, N-acetylcysteine, ondanseteron, pioglitazone, piracetam, gingko biloba, progesterone, propranolol, cocaine-metabolizing fusion protein TV-1380 (AlbuBChE),
Amphetamine/methamphetamine use disorder
--- | 3 | Opiate agonists | buprenorphine + naloxone; buprenorphine vs methadone
1 | --- | Psychostimulants | Bupropion
--- | 1 | Anticonvulsants | Baclofen vs gabapentin
--- | 3 | Antidepressants | Bupropion, mirtazapine, sertraline
--- | 2 | Antipsychotics | Aripiprazole
--- | 4 | Medications for other SUD | Naltrexone
--- | 1 | Muscle relaxants/anticonvulsants | Topiramate
--- | 3 | Other pharmacotherapies | 1 trial of each: citicoline, ondansetron, PROMETA

Abbreviations: RCT = randomized controlled trial; SR= systematic review; SUD = substance use disorder

## Key Question 1 What are the benefits and harms of pharmacotherapy for cocaine use disorder?

### Summary of Findings

Our search of pharmacotherapies for cocaine use disorder identified 7 systematic reviews^5,11–16^ and 46 RCTs^17–62^ that were not included in previous systematic reviews. Table 2 lists the pharmacotherapies examined by the included studies.

It is difficult to draw strong conclusions given the limitations of this body of evidence. Many of the studies were small trials with limited power, methodologic deficiencies, and high enough attrition rates to further limit assessment of treatment effectiveness. Across studies there was significant variability in population, setting, co-interventions, the number of study visits and UAs per week, and the outcomes reported. Overall, we found insufficient to low strength evidence that most of the drug classes examined did not improve abstinence, use, or retention.

There were a handful of exceptions with findings suggesting a positive benefit of pharmacotherapy over placebo. We found low strength evidence that bupropion and topiramate were more effective than placebo in achieving sustained abstinence of 2 or more weeks. In addition, we found low strength evidence that for participants who are abstinent at baseline, sertraline is better than placebo at preventing both lapse (first cocaine-positive UA) and relapse (2 consecutive cocaine-positive UAs). For study retention, there is moderate strength evidence of better retention for participants receiving any antipsychotic. However, we found no benefit on retention when examining first- or second-generation antipsychotics (as classes), or any specific antipsychotic individually.

We also found evidence of potential downsides to the use of certain pharmacotherapies. A meta-analysis of 7 RCTs20,21,31,40,52,63,64 provides moderate strength evidence for lower rates of study retention among participants randomized to disulfiram (compared to placebo). In addition, there is moderate strength evidence of a higher risk of study withdrawal due to adverse events associated with SSRIs versus placebo.

Studies of individuals with comorbid cocaine and opioid use disorders were limited. Similar to the entire cocaine use disorder population, the vast majority of findings were either null or were insufficient from which to draw conclusions. We did find low strength evidence that participants receiving antidepressants as a class and bupropion specifically were more likely to achieve sustained abstinence. However, in the meta-analysis comparing disulfiram to placebo for study retention, 6^21,31,40,52,63,64^ of 7 included trials were conducted in subjects with comorbid opioid use disorder, and provide moderate strength evidence that participants randomized to disulfiram are less likely to complete treatment.

### Antidepressants

#### Summary of Findings

One systematic review^16^ and 4 subsequent trials^17,36,41,46^ provide evidence on the use of antidepressants for cocaine use disorder. One additional systematic review provides data on the use of bupropion.^5^ Overall, studies found a non-significant trend favoring antidepressants as a class over placebo for sustained abstinence (SOE moderate), and no difference in study period use (SOE moderate), retention (SOE high), or harms (SOE moderate/low). There is low strength evidence that bupropion is significantly better than placebo for sustained abstinence. There is also low strength evidence that in participants who are abstinent at baseline, sertraline is better than placebo at preventing lapse and relapse. Finally, there is moderate strength evidence of a higher risk of withdrawal from treatment due to adverse events associated with SSRIs versus placebo. No other significant differences were identified.

#### Detailed Findings

A previous systematic review^16^ and 4 more recent trials^17,36,41,46^ provide evidence on the use of antidepressants for cocaine use disorder. The systematic review^16^ included 37 studies (3,551 participants) of tricyclics (18 studies), selective serotonin reuptake inhibitors (SSRIs; 8 studies), and other antidepressants including bupropion, nefazodone, and venlafaxine. One additional systematic review provides data on the use of bupropion.^5^ Our search identified more recent trials of sertraline,^36,41^ venlafaxine,^46^ and mirtazapine.^17^

There is moderate strength evidence that antidepressants as a class are no better than placebo for sustained abstinence; however, there is a trend favoring antidepressants. The systematic review included 8 RCTs (N=942) comparing any antidepressant to placebo on 3-or-more-week abstinence rates and found no significant difference (combined RR 1.22 [95% CI 0.99 to 1.51]).^16^ Similarly, a recent study (N=130) reported no difference between venlafaxine and placebo on the number of participants achieving negative UAs for a period of 3 weeks or longer.^46^ We found moderate strength evidence of no difference between antidepressants and placebo for benefit on cocaine use during the trial period. Findings were consistent across 4 RCTs from the systematic review (N=251; combined RR 1.05 [95% CI 0.91 to 1.21]) and 2 additional RCTs.^17,46^ Twenty-seven RCTs from the systematic review^16^ (N= 2,417; combined RR 1.01 [95% CI 0.91 to 1.12]) and 3 additional RCTs^36,41,46^ provide high strength evidence that antidepressants are no better than placebo for study retention, and we identified no difference between antidepressants and placebo on severe adverse events or the number of study withdrawals due to adverse events.

We identified evidence from 2 studies^36,41^ of antidepressants in participants who were abstinent from cocaine at baseline. These studies combined provide low strength evidence that antidepressants are better than placebo for preventing both lapse and relapse (see Table 3 for study-level data and Conclusions Table A for a summary of findings).

##### Tricyclic Antidepressants: Desipramine

One systematic review provided evidence of the effect of tricyclic antidepressants (TCAs) for cocaine use disorder.^16^ The review included 18 studies examining tricyclics, 17 of which examined desipramine. There is low strength evidence of no difference between TCAs/desipramine and placebo for sustained abstinence. Although 5 RCTs in the review favor TCAs over placebo for sustained abstinence (N=367; combined RR 1.55 [95% CI 1.10 to 2.17]), no difference remained when limiting analyses to trials requiring a DSM diagnosis of cocaine use disorder (N=234; combined RR 1.41 [95% CI 0.93 to 2.14]). Findings from 2 underpowered RCTs in the review indicate no difference between desipramine and placebo for cocaine use during the trial period; however, the evidence is insufficient (2 RCTs; N=37; combined RR 0.85 [95% CI 0.34 to 2.11]). There is moderate strength of evidence that there is no difference between desipramine and placebo for retention (13 RCTs; N=1,011; combined RR 1.06 [95% CI 0.95 to 1.20]) or treatment withdrawals due to adverse events (4 RCTs; N=268; combined RR 1.42 [95% CI 0.68 to 2.96]) (see Conclusions Table A for a summary of findings). No other significant differences were found.

##### Selective Serotonin Reuptake Inhibitors (SSRIs)

One systematic review^16^ and 2 additional trials^36,41^ examine the use of SSRIs, specifically paroxetine, fluoxetine, and sertraline, for cocaine use disorder (the review also grouped nefazodone, a serotonin antagonist and reuptake inhibitor, as an SSRI). There is no evidence examining the effect of SSRIs on sustained abstinence or study period cocaine use in participants who were not abstinent at baseline. Two studies^36,41^ provide low strength evidence that sertraline is better than placebo for preventing lapse and relapse in participants who have achieved abstinence (see sertraline below for more detail). Two low-ROB RCTs^36,41^ and 7 RCTs in the systematic review provide moderate strength evidence that SSRIs do not improve study retention (N=527; combined RR 0.99 [95% CI 0.70 to 1.71]), and 3 RCTs in the systematic review provide moderate strength evidence of a higher risk of study withdrawal due to adverse events associated with SSRIs versus placebo (N=251; combined RR 3.55 [95% CI 1.11 to 11.34]). No trials provided evidence comparing SSRIs to placebo on serious adverse events (see Table 3 for study-level details and Conclusions Table A for a summary of findings).

##### Fluoxetine

Five trials in the systematic review examined fluoxetine.^16^ We found no evidence examining the effect of fluoxetine on sustained abstinence, study period cocaine use, or serious adverse events. Four RCTs in the systematic review provide moderate strength evidence that fluoxetine performs worse than placebo on study retention (N=430, combined RR 1.30 [95% CI 1.08 to 1.57]). Similarly, 2 RCTs in the review provide low strength evidence of a higher risk of treatment withdrawal due to adverse events associated with fluoxetine (N=218; combined RR 3.60 [95% CI 1.03 to 12.62]). Conclusions Table A provides a summary of findings.

##### Sertraline

Two low risk of bias trials provide evidence examining sertraline for the treatment of cocaine use disorder in participants with comorbid depression (N=133).^36,41^ There is low strength evidence of lower risk for both lapse (combined RR 0.79 [95% CI 0.62 to 1.00]; P= 0.05) and relapse (combined RR 0.74 [95% CI 0.57 to 0.96]; P = 0.02) for participants receiving sertraline (see Figures 3 and 4). Both studies were 12-week trials, with a 2-week residential stay, followed by 10 weeks of outpatient study visits. Only participants achieving abstinence by the end of week 2 progressed to the outpatient phase. Participants received 200mg of sertraline or placebo, along with contingency management, and once weekly CBT. Neither study found a difference between groups in study retention (see Table 3 for study-level details and Conclusions Table A for a summary of findings).

Figure 3 Lapse after initial abstinence in studies comparing sertraline vs placebo for cocaine use disorder

Figure 4 Relapse after initial abstinence in studies comparing sertraline vs placebo for cocaine use disorder

##### Serotonin and Norepinephrine Reuptake Inhibitor (SNRI): Venlafaxine

One low-ROB, 12-week, placebo-controlled trial examined venlafaxine for cocaine use disorder (N=130) in adults with comorbid depression.^46^ Participants received up to 300mg of venlafaxine or placebo, along with motivational interviewing and weekly manualized relapse prevention therapy. No significant differences in sustained abstinence, study period negative UAs, retention, or harms were reported (see Table 3 for study-level details and Conclusions Table A for a summary of findings).

##### Atypical Antidepressant: Mirtazapine

One small, high-ROB, 20-week trial (N=24) compared mirtazapine to placebo for adults with cocaine dependence and clinically significant depressive symptoms.^17^ Participants received 45mg of mirtazapine or placebo for 12 weeks (plus tapering up and down by 15mg every 3 days), in addition to weekly relapse prevention therapy. No difference was reported for study period use, and no treatment withdrawals due to adverse events or severe adverse events were reported (see Table 3 for study-level details and Conclusions Table A for a summary of findings).

##### Aminoketone: Bupropion

Bupropion as a treatment for cocaine use disorder was included in systematic reviews examining both antidepressants^16^ and psychostimulants.^5^ Outcomes reported were slightly different and we include the most comprehensive. Two RCTs in one systematic review^5^ provide low strength evidence that bupropion is more beneficial than placebo for sustained abstinence (N=176; combined RR 1.63, 95% CI 1.03 to 2.59). No difference was found for cocaine use during the trial period (SOE low),^5^ study retention (SOE moderate),^16^ or harms (see Table 3 for study-level details and Conclusions Table A for a summary of findings).^16^

Table 3 Trials of antidepressants for treating cocaine use disorder

Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Abstinence, Lapse or Relapse: ≥2 weeks, N (%) and/or longest consecutive period, mean (SD) | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
ATYPICAL ANTIDEPRESSANTS: Mirtazapine
Afshar, 2012^17^ NR sites (US) N=24 20 wks follow-up | 11 vs 13 Mitrazapine 45 mg/day 12 wks 60 mins 1x/wk individual relapse prevention counseling NR (UA1+ /wk) | 71% male Age: 45.5 Race: 8% White, 79% AA/Black Education & Employment: NR | NR | Use declined significantly for both groups, with no difference between groups. | NR | WD: 0 Severe AEs: None | High
SELECTIVE SEROTONIN REUPTAKE INHIBITORS (SSRIs): Sertraline
Mancino, 2014^36^ 1 site (US) N=107 residential, 74 outpatient 13 wks follow-up | Residential: 35 vs 34 vs 38 Outpatient (analyzed): 23 vs 24 vs 27 Sertraline 200 mg/day; Sertraline 200 mg/day + Gabapentin 1200mg 12 wks Wks 1–2: residential treatment. Wks 3–12: CM + 60 min 1x/wk individual CBT UA 3x/wk | 77% Male Age: 39.5 (7.3) Race: 71.6% AA/Black; White NR Employment: 62% unemployed Education: 57% High school or less | N (%) Lapse: 16 (69.6%) vs 17 (70.8%) vs 24 (88.9%), P = NS N (%) Relapse: 15 (65.2%) vs 17 (70.8%) vs 24 (88.9%) SERT vs PLA, P = 0.04 No difference in the time to lapse or relapse. | NR | 74 of 107 completed residential phase: 23 (66%) vs 24 (71%) vs 27 (71%) 23 of 74 completed outpatient phase: 8 (35%) vs 9 (38%) vs 6 (22%) | WD (during residential phase): 0 (0%) vs 1 (3%) vs 0 (0%). Severe AEs: NR | Low
Oliveto, 2012^41^ 1 site (US) N=94 residential, 64 outpatient, 59 analyzed 13 wks follow-up | Residential: 50 vs 44 Outpatient (analyzed): 32 vs 27 Sertraline 200 mg/day 12 wks Wks 1–2: Residential Wks 3–12: CM + 60 min 1x/wk CBT UA 3x/wk | 61% male Age: 38.3 Race: 27% White, 66% AA/Black Education: 8.9 yrs (4.2) Employment: 66% unemployed or less than part-time | N (%) Lapse: 18 (56%) vs 19 (70%), P = 0.14 N (%) Relapse: 17 (53%) vs 19 (70%), P = 0.07 M time to Lapse: 26.1 (±16.7) vs 13.2 (±10.5), P = 0.004 M time to Relapse 32.3 (±14.9) vs 21.3 (±10.8), P = 0.02 | NR | No significant difference in residential or outpatient retention by group. | WD: 2 (group NR) Severe AEs: NR | Low
SEROTONIN AND NOREPINEPHRINE REUPTAKE INHIBITORS (SNRIs): Venlafaxine
Raby, 2014^46^ 1 site (US) N=130 12 wks follow-up | 64 vs 66 Venlafaxine Up to 300 mg/day 12 wks 1x/wk individual relapse prevention therapy (CBT, MI) UA 2x/wk | 72.5% Male Age: 38.5 (8) Race: 39% White, 26% AA/Black Education: 46% high school or less Employment: 16% Unemployed Veteran pop: very few Veterans despite VA study (per author email) | N (%) 3+ wks abstinent: 10 (16%) vs 10 (15%), P = 0.94 | Proportion of UA (-): 0.58 vs 0.56, P = 0.738 | 53 completed study: 21 (33%) vs 32 (49%) No difference in wks to dropout by group. | WD: 1 (2%) vs 3 (5%) Severe AEs: 6 (9%) vs 0 (0%) | Low

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AE = adverse event; AA = African American; C = control group; CBT = Cognitive Behavioral Therapy; CI = confidence interval; hr = hour(s); CM = contingency management; US = United States of America; MA = methamphetamine; mg = milligrams; MI = Motivational Interviewing; MTD = maximum tolerated dose; NR = Not reported; NS = not significant; OR = Odds ratio; P = p-value; PLA = placebo; ROB = risk of bias; SD = standard deviation; SEM = standard error of the mean; SERT = sertraline; SES = socioeconomic status; sig = statistically significant; SNRI = serotonin and norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor; T = treatment group; TTM = Transtheoretical Model; UA = urinalysis; wk(s) = week(s); yrs = years.

### Antipsychotics

#### Summary of Findings

One systematic review^12^ and 1 high-ROB RCT^39^ examine the evidence for the use of antipsychotics for the treatment of cocaine use disorder. Overall, there was moderate strength evidence of better retention for participants receiving any antipsychotic. However, there was no benefit on retention when examining first- or second-generation antipsychotics as a class, or any antipsychotic individually. Findings suggest that antipsychotics as a class or individually are no better than placebo for sustained abstinence (ie, 2+ weeks; SOE low), study period cocaine use (SOE low), preventing relapse or lapse in abstinent participants, or harms.

#### Detailed Findings

One high-ROB RCT of methadone-maintained participants^39^ and 1 systematic review^12^ of 14 RCTs (n = 719) that largely examined second-generation antipsychotics (ie, aripiprazole, olanzapine, quetiapine, risperidone), along with haloperidol, lamotrigine, and reserpine, provided evidence for antipsychotics for the treatment of cocaine use disorder. Overall, findings indicate low strength evidence of no difference between antipsychotics and placebo for both sustained abstinence^12^ and cocaine use during the study period,^12,39^ and insufficient evidence for lapse and relapse in participants abstinent at baseline.^39^ Based on findings from 8 RCTs in the systematic review (N=397; combined RR 0.75 [95% CI 0.57 to 0.97]),^12^ moderate strength evidence exists to support the benefit of antipsychotics over placebo for study retention. We found no difference between antipsychotics as a class and placebo in treatment withdrawal due to adverse events (see Table 4 for study-level details and Conclusions Table A for a summary of findings).^39^

##### First-generation (Typical) Antipsychotics/Haloperidol

One RCT in 1 systematic review^12^ found no difference between haloperidol and placebo in study retention. In addition, a head-to-head trial found no difference between haloperidol and olanzapine (N=31; RR 1.50 [95% CI 0.63 to 3.57]). We found no evidence for the effect of any typical antipsychotic on sustained abstinence, study period cocaine use, or harms (see Conclusions Table A for a summary of findings).

##### Second-generation (Atypical) Antipsychotics

One systematic review^12^ and 1 small, high-ROB RCT of methadone-maintained participants^39^ examined atypical antipsychotics aripiprazole, olanzapine, quetiapine, and risperidone for the treatment of cocaine use disorder. Findings from the systematic review indicate no difference between atypical antipsychotics and comparators for sustained abstinence (SOE low), study period use of cocaine, retention (SOE moderate), or harms;^12^ moreover, no difference was found in relapse or lapse in methadone-maintained participants at baseline.^39^ Head-to-head trials in the systematic review found no difference in retention between olanzapine and haloperidol (1 RCT; N=31), olanzapine and risperidone (1 RCT; N=28), and aripiprazole and ropinirole (1 RCT; N=28; see Table 4 for study-level details and Conclusions Table A for a summary of findings).^12^

##### Aripiprazole

One small, high-ROB RCT^39^ examined aripiprazole, along with contingency management and individual counseling, in opioid-dependent methadone-maintained adults. Participants first went through a 12-week methadone stabilization phase that included contingency management and (unspecified) treatment, and those who achieved cocaine abstinence in weeks 11 and 12 were randomized to 15mg of aripiprazole or placebo (N=18), with contingency management continuing through the 2-week induction phase. Time to both lapse (first cocaine-positive urine sample; HR=0.45, 95% CI [0.14 to 1.42], P=0.17) and relapse (2 consecutive cocaine-positive urine samples or missed urines; (HR= 0.31, 95% CI [0.07 to 1.27], P=0.10) were similar between groups, and there was no difference in the longest duration of abstinence. The study was discontinued early due to the small number of participants (18 of 41 enrolled) able to achieve abstinence in weeks 11 and 12. One additional RCT in a systematic review^12^ compared aripiprazole to ropinirole and found no difference in retention (see Table 4 for study-level details and Conclusions Table A for a summary of findings).

##### Risperidone

Evidence examining risperidone for the treatment of cocaine use disorder comes from 1 systematic review.^12^ One small RCT (N=31) in the systematic review found no difference between risperidone and placebo in the use of cocaine during the study period. In addition, 4 RCTs in the systematic review found a non-significant trend in favor of risperidone for study retention (N=176; combined RR 0.81 [95% CI 0.63 to 1.04]; SOE low), and a head-to-head trial found no difference between risperidone and olanzapine (N=28). No other outcomes were examined (see Conclusions Table A for a summary of findings).

##### Olanzapine

One systematic review provides evidence examining the use of olanzapine for the treatment of cocaine use disorder.^12^ Two underpowered RCTs found no difference between olanzapine and placebo, but provide insufficient evidence for the effect on end-of-study abstinence (N=79, combined RR 1.37 [95% CI 0.71 to 2.61]). In addition, there were no differences in participants completing RCTs comparing olanzapine to placebo (N=30; RR 2.00 [95% CI 0.20 to 19.78]), haloperidol (N=31; RR 1.50 [95% CI 0.63 to 3.57]), and risperidone (N=28; RR 2.00 [95% CI 0.78 to 5.14]; see Conclusions Table A for a summary of findings).

##### Quetiapine

One systematic review provides evidence examining quetiapine for adults with cocaine use disorder.^12^ One RCT (N=60) in the review found no difference between quetiapine and placebo for end-of-trial abstinence (last 2 weeks), and 2 RCTs found no difference in study retention (N=72; combined RR 0.64 [95% CI 0.20 to 2.03]). No other outcomes of interest were examined (see Conclusions Table A for a summary of findings).

##### Other Antipsychotics: Reserpine

One RCT in a systematic review^12^ compared reserpine to placebo for cocaine use. No differences were found between groups during the study. No other outcomes of interest were examined (see Conclusions Table A for a summary of findings).

Table 4 Trials of antipsychotics for treating cocaine use disorders

Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Time to lapse and relapse, UA-confirmed | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
ATYPICAL ANTIPSYCHOTICS: Aripiprazole
Moran, 2017^39^ 1 site (US) N=18 (41 enrolled) All Ss abstinent at baseline 41wks follow-up | 9 vs 9 Aripiprazole 15mg/day (MTD) 12 wks CM during 2-week induction UA 3x /wk | 94% Male Age: 46 Race: 12.5% White, 81% AA/Black Education: 12.5 yrs Unemployed: 12.5% | M (SEM) longest duration of abstinence: 20.11 (4.87) vs 14.89 (4.19), P = 0.43 Time to Lapse: There was no difference in time to lapse (HR = 0.51, 95% CI [0.18, 1.48], P = 0.21]. Time to Relapse: There was no difference in time to lapse. | M% (SEM) of UA (-) samples: 58% (12%) vs 55% (11%), P = 0.66 | 8 (89%) vs 6 (67%) | WD: 0 (0%) vs 1 (11%) Severe AEs: NR | High

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AE = adverse event; AA = African American; C = control group; CBT = Cognitive Behavioral Therapy; CI = confidence interval; hr = hour(s); CM = contingency management; US = United States of America; MA = methamphetamine; mg = milligrams; MI = Motivational Interviewing; MTD = maximum tolerated dose; NR = Not reported; NS = not significant; OR = Odds ratio; P = p-value; ROB = risk of bias; SD = standard deviation; SEM = standard error of the mean; SES = socioeconomic status; sig = statistically significant; T = treatment group; TTM = Transtheoretical Model; UA = urinalysis; wk(s) = week(s); yrs = years

### Psychostimulants

#### Summary of Findings

We identified 1 systematic review^5^ examining psychostimulants for the treatment of cocaine use disorder. Overall, studies found low strength evidence favoring the use of psychostimulants as a class for sustained abstinence generally, and dexamphetamine and mixed amphetamine salts specifically (both insufficient SOE). There was moderate strength evidence of no differences for retention and harms. Note, this body of literature is hampered by low-quality studies, with consistent concerns related to incomplete outcome data.

#### Detailed Findings

A 2016 systematic review^5^ included 26 trials (N=2366) and examined modafinil, mazindol, methylphenidate, dexamphetamine, lisdexamfetamine, methamphetamine, mixed amphetamine salts, and selegiline. The review also included studies of bupropion, which was also examined in the included systematic review for antidepressants.^16^ We have classified bupropion as an antidepressant (see Conclusions Table A for a summary of findings).

Findings from 14 RCTs in the systematic review indicate low strength evidence that psychostimulants as a class are better than placebo for sustained abstinence (N=1,549; combined RR 1.36 [95% CI 1.05 to 1.77]). One bupropion study was included in the combined estimate; however, its removal does not change the conclusion.^65^ There were no significant differences between groups for cocaine use during the trial period (SOE low), study retention (SOE moderate), or harms (SOE moderate; see Conclusions Table A for a summary of findings).

##### Dexamphetamine

Findings come from 1 systematic review^5^ that included 4 RCTs examining dexamphetamine. Three high-ROB RCTs in the review examined sustained abstinence and found that dexamphetamine was significantly better than placebo (N=154; combined RR 1.98 [95% CI 1.12 to 3.52]). The strength of evidence however, is insufficient due to concerns about incomplete outcome data for all 3 studies and questions related to random sequence generation and blinding. No other significant differences between dexamphetamine and placebo were identified (see Conclusions Table A for a summary of findings).

##### Mazindol

Four RCTs in the systematic review examine mazindol for the treatment of cocaine use disorder.^5^ One underpowered, high-ROB trial in the review found no significant difference between mazindol and placebo for sustained abstinence, and 4 underpowered RCTs (2 unclear, 2 high-ROB) in the systematic review found no difference between groups in study retention (N=121; combined RR 0.96 [95% CI 0.76 to 1.21]). No other outcomes of interest were examined (see Conclusions Table A for a summary of findings).

##### Methamphetamine

One high-ROB RCT in the systematic review^5^ found no significant difference between methamphetamine and placebo in retention or study withdrawals due to adverse events in the treatment of cocaine use disorder. No other outcomes of interest were examined (see Conclusions Table A for a summary of findings).

##### Methylphenidate

Four high-ROB RCTs in the systematic review^5^ examined methylphenidate for the treatment of cocaine use disorder. One RCT found that methylphenidate did not differ from placebo on sustained abstinence. Three trials (N=203) found no difference between groups for cocaine use during the trial period (SMD −0.09 [95% CI −0.36 to 0.19]; SOE low) or retention (combined RR 0.91 [95% CI 0.68 to 1.21]; SOE low). Three RCTs found no difference between groups in study withdrawals due to adverse events (N=216; combined RD −0.01 [95% CI −0.05 to 0.03]; SOE low; see Conclusions Table A for a summary of findings).

##### Mixed Amphetamine Salts

One unclear-ROB RCT in the systematic review^5^ compared mixed amphetamine salts to placebo for the treatment of cocaine use disorder. Although the evidence is insufficient due to the single study and questions related to blinding and incomplete outcome data, the study found that mixed amphetamine salts performed better than placebo for sustained abstinence (N=126; RR 3.63 [95% CI 1.15 to 11.48]). No differences were reported for retention or harms (see Conclusions Table A for a summary of findings).

##### Modafinil

Eight RCTs in the systematic review^5^ examined modafinil for the treatment of cocaine use disorder. All but 2 included RCTs were high-ROB, with concerns about incomplete outcome data, as well as questions about random sequence generation, allocation concealment, and blinding. The review found no significant differences between groups for abstinence (6 RCTs; N=644; combined RR 1.32 [95% CI 0.85 to 2.04]; SOE low), use (1 RCT; N=57), retention (7 RCTs; N=723; combined RR 1.04 [95% CI 0.89 to 1.21]; SOE moderate), or harms (4 RCTs; SOE moderate; see Conclusions Table A for a summary of findings).

##### Lisdexamphetamine

One small, high-ROB study (N=43) in the systematic review^5^ compared lisdexamphetamine to placebo for the treatment of cocaine use disorder. No significant differences on retention or harms were reported. No other outcomes of interest were examined (see Conclusions Table A for a summary of findings).

##### Selegiline

One high-ROB study (N=300) in the systematic review^5^ examined selegiline for the treatment of cocaine use disorder. No differences were reported for sustained abstinence, study retention, or harms. No other outcomes of interest were examined (see Conclusions Table A for a summary of findings).

### Cognitive Enhancing Drugs

#### Summary of Findings

Two small RCTs^19,61^ examined cognitive enhancing drugs plus contingency management for the treatment of cocaine use disorder. One low-ROB trial compared memantine to placebo,^19^ and the second was an unclear-ROB trial comparing atomoxetine to placebo.^61^ Neither study reported significant differences on any outcome of interest.

#### Detailed Findings

Two small RCTs^19,61^ examined cognitive enhancing drugs plus contingency management for the treatment of cocaine use disorder. One low-ROB, placebo-controlled trial (N=81) that had a 2-week placebo lead in to encourage abstinence examined memantine,^19^ and the second, an unclear-ROB trial (N=50) compared atomoxetine to placebo.^61^ Neither study reported significant differences on any outcome of interest.

##### Memantine

One low-ROB trial^19^ compared memantine (a NMDA receptor antagonist) to placebo for the treatment of cocaine use disorder. Participants (N=112) began the trial with 2 weeks of (single-blind) placebo lead-in to encourage abstinence. All participants received Motivation Enhancement Therapy (MET; weeks 1–4), high-value contingency management (weeks 1–4), and Cognitive Behavioral Treatment-Relapse Prevention (CBT-RP; weeks 3–16). In week 3, remaining participants were randomized (n=81) to 40mg of memantine or placebo. There was no difference between groups for sustained abstinence (χ^2^(1)= 0.29, P=0.59), cocaine use (β=0.03, SE=0.17, χ^2^ (1)=0.03, P=0.87), or study retention (χ^2^(3)=0.89, P=0.83). In addition, among those participants who had achieved abstinence at baseline, there was no significant difference in relapse or time to relapse (see Table 5 for study-level details and Conclusions Table A for a summary of findings).

##### Atomoxetine

One small, 12-week, unclear-ROB trial^61^ compared 80mg of atomoxetine, a cognitive enhancing serotonin norepinephrine reuptake inhibitor (SNRI), to placebo, along with contingency management and optional weekly CBT-based relapse prevention counseling for the treatment of cocaine use disorder. Findings indicate no significant differences in cocaine use during the study (χ^2^=0.2, P=0.66; OR=0.89 [95% CI 0.41 to 1.74]), study retention (Cox analysis χ^2^=0.72, P=0.40; Hazard Ratio 1.48 [95% CI 0.62 to 3.39]), or treatment withdrawal due to adverse events (see Table 5 for study-level details and Conclusions Table A for a summary of findings).

Table 5 Trials of cognitive-enhancing drugs for treating cocaine use disorder

Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Abstinence or relapse UA-confirmed: ≥2 weeks, N (%) and/or longest consecutive period, mean (SD) | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
Memantine
Bisaga, 2010^19^ 1 site (US) N=112 16 wks follow-up | 39 vs 42 Memantine 40 mg/day 12 wks CM (weeks 1–4), MET (weeks 1–4), 1x/week relapse prevention therapy (CBT) UA 3x/wk | 79% Male Age: 40 Race: 41% White 40% AA/Black Education: 48% high school Unemployment: 42% unemployed | N (%) Relapse among subjects who achieved abstinence at baseline (N=36): 15 (80%) vs 15 (88%) N (%) 3+ wk abstinence among subjects who achieved abstinence at baseline (N = 36): 11 (58%) vs 10 (59%) Median time to relapse among subjects who achieved abstinence at baseline (N = 36): 2 wks vs 3 wks, P = 0.32 N (%) 3+ wk abstinence among those not abstinent at baseline (N=45): 4 (19%) vs 3 (13%), P = 0.59 | No difference, P = 0.87 | 49 completed study: 22 (56%) vs 27 (64%) | WD: 2 (5%) vs 0 (0%) Severe AEs: 0 (0%) vs 2 (5%) | Low
Cognitive enhancing SNRI: Atomoxetine
Walsh, 2013^61^ 1 site (US) N=50 24 wks follow-up | 25 vs 25 Atomoxetine 80 mg/day 12 wks CM + Optional 1x/week individual relapse prevention therapy (CBT and coping skills) UA 3x/wk | 72% Male Age: 43.1 Race: 32% White, 68% AA/Black Education: 12.55 yrs Employment: 76% unemployed | NR | % of study period UA (-): 26% vs 33%, P = 0.66 | 28 completed study: 12 (48%) vs 16 (64%), P = 0.40 M days completed: 51.6 (±6.7) vs 57.4 (±7) | WD: 1 (4%) vs 0 (0%) Severe AEs: NR | Unclear

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AE = adverse event; AA = African American; C = control group; CBT = Cognitive Behavioral Therapy; CI = confidence interval; hr = hour(s); CM = contingency management; US = United States of America; MA = methamphetamine; MET = motivational enhancement therapy; mg = milligrams; MI = Motivational Interviewing; MTD = maximum tolerated dose; NR = Not reported; NS = not significant; OR = Odds ratio; P = p-value; ROB = risk of bias; SD = standard deviation; SEM = standard error of the mean; SES = socioeconomic status; sig = statistically significant; T = treatment group; TTM = Transtheoretical Model; UA = urinalysis; wk(s) = week(s); yrs = years.

### Anxiolytics

#### Summary of Findings

We identified 1 RCT examining an anxiolytic for the treatment of cocaine use disorder. A small, multi-site, high-ROB RCT compared buspirone to placebo for treatment and relapse prevention.^62^ No significant differences were reported for any outcome of interest.

#### Detailed Findings

##### Buspirone

One small, multi-site, 16-week, high-ROB RCT (N=62) compared 60mg of buspirone to placebo, along with contingency management and once-weekly optional individual or group psychosocial treatment for treatment and relapse prevention in adults with cocaine use disorder.^62^ Participants were randomized to buspirone or placebo, then spent 12–19 days in residential treatment before continuing care in an outpatient setting. Urinalyses were performed once weekly. No differences were reported for the mean number of post-discharge days abstinent (χ^2^(1)=0.05, P=.82) or time to lapse (χ^2^(1)=0.15, P=0.70). Rates of retention were similarly high in both groups, and 3 participants receiving buspirone experienced a severe adverse event (see Table 6 for study-level details and Conclusions Table A for a summary of findings).

Table 6 Trials of anxiolytics for treating cocaine use disorder

Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES | Abstinence or relapse UA-confirmed: ≥2 weeks, N (%) and/or longest consecutive period, mean (SD) | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
ANXIOLYTICS: Buspirone
Winhusen, 2014^62^ 6 sites (US) N=62 12–19 days residential, remaining outpatient 16 wks follow-up | 35 vs 27 Buspirone 60 mg/day or MTD 15 wks CM, Inpatient/residential (psychosocial TAU, Outpatient TAU (min of 60 min 1x/wk individual or group psychosocial treatment) UA 1x/wk | 63% Male Age: 46 Race: 22.6% White, 72.6% African Am Education: 11.6 yrs (1.8) Employment: NR | M (SD) days of continuous (post-discharge) abstinence: 39.7 (31.4) vs 42.1 (31.1), P = 0.82 No significant difference in days to first cocaine use, P = 0.70 | NR | 33 (94%) vs 25 (93%) | WD: None Severe AEs: 3 (9%) vs 0 (0%) | High

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AE = adverse event; AA = African American; C = control group; CBT = Cognitive Behavioral Therapy; CI = confidence interval; hr = hour(s); CM = contingency management; US = United States of America; MA = methamphetamine; MET = motivational enhancement therapy; mg = milligrams; MI = Motivational Interviewing; MTD = maximum tolerated dose; NR = Not reported; NS = not significant; OR = Odds ratio; P = p-value; ROB = risk of bias; TAU = treatment as usual

### Pharmacotherapies That are Prescribed for Other Substance Use Disorders

#### Disulfiram

##### Summary of Findings

Findings from 5 RCTs^20,21,31,40,52^ identified in our search and 2 RCTs^63,64^ identified by a previous systematic review^15^ indicate that subjects randomized to disulfiram were less likely to complete treatment compared with placebo (moderate SOE). The increased attrition with disulfiram was marginally significant in a meta-analysis combining the 7 trials. The effects of disulfiram on overall cocaine use were heterogeneous (insufficient SOE). No effect on abstinence was observed (low SOE). No difference in harms was reported (low SOE).

##### Abstinence

From 2 low-ROB RCTs^20,52^ (N=276) combined with 1 unclear-ROB RCT (N=20),^63^ there was low strength of evidence of no significant difference in the number of patients who achieved abstinence for 2 or more consecutive weeks (RR 0.96, 95% CI 0.63 to 1.45). Statistical heterogeneity among the studies combined in this analysis was not significant (p=0.83; See Figure 5 for meta-analysis, Table 7 for study-level data and Conclusions Table B for a summary of findings).

Figure 5 Abstinence for 2+ consecutive weeks in studies comparing disulfiram vs placebo in patients with cocaine use disorder

##### Use

Among 4 low-ROB RCTs^20,21,31,40^ (N=440) there was insufficient strength of evidence for no significant difference in the total number of cocaine-negative UA samples among patients treated with disulfiram compared with placebo (RR 0.95, 95% CI 0.64 to 1.39). The effects of treatment varied markedly, however, and statistical heterogeneity among the studies combined in this analysis was highly significant (P <.00001; See Figure 6 for meta-analysis, Table 7 for study-level data, and Conclusions Table B for a summary of findings).

Figure 6 Overall use: Total cocaine-negative UA samples in studies comparing disulfiram vs placebo in patients with cocaine use disorder

##### Retention

We found moderate-strength evidence that treatment retention tended to be lower among patients treated with disulfiram compared with placebo for cocaine use disorder based on 5 low-ROB RCTs (N=617),^20,21,31,40,52^ combined with 1 small (N=20) unclear-ROB RCT^63^ and 1 high-ROB RCT^64^ (N=67). In a meta-analysis combining the 7 trials, decreased retention with disulfiram was marginally significant (RR 0.90, 95% CI 0.83 to 0.99). The findings were statistically homogeneous among studies, with a P-value of .90 for heterogeneity. See Figure 7 for meta-analysis, Table 7 for study-level data, and Conclusions Table B for a summary of findings.

Figure 7 Treatment retention in studies comparing disulfiram vs placebo in patients with cocaine use disorder

##### Harms

Withdrawals due to AEs ranged from 0% to 5.9% among the 4 RCTs (N=548) identified in our search, for reasons that included elevated liver enzymes and rash.^21,31,40,52^ The occurrence of severe adverse events was not otherwise reported. The strength of evidence for harms is therefore considered low.

#### Naltrexone

Five low-ROB RCTs compared naltrexone with placebo.^23,42,43,50,51^ No differences were reported for any of the outcomes of interest. See Table 7 for study-level data and Conclusions Table B for a summary of findings.

#### Acamprosate

One low-ROB trial (N=60) compared acamprosate with placebo in patients with cocaine use disorder. The study found no significant differences in retention or overall use.^28^ Effects on abstinence and adverse effects were not reported. See Table 7 for study-level data and Conclusions Table B for a summary of findings.

#### Varenicline

Two unclear-ROB trials (N=68) compared varenicline with placebo, with mixed results. Cocaine use was lower with varenicline in 1 study, though this finding did not reach statistical significance (OR 0.495, p = 0.08).^44^ The other study was conducted in opioid-dependent patients (N=31) and reported similar cocaine use between varenicline and placebo groups.^45^ No differences in study retention were observed, and continuous abstinence was not reported in either study.

### Opiate Agonists

#### Buprenorphine vs Methadone

Two low-ROB, head-to-head RCTs (N=278) compared methadone to buprenorphine in patients with comorbid cocaine and opioid use, and reported mixed findings on retention and abstinence.^53,54^ Longer abstinence and better retention with methadone was found in 1 RCT. Use outcomes favored methadone over buprenorphine (P<.05); however, the strength of evidence was insufficient. See Table 7 for study-level data and Conclusions Table B for a summary of findings.

#### Buprenorphine plus Naloxone

In 1 low-ROB RCT (N=302), there was no difference in abstinence and retention outcomes. There were mixed findings in use, with significantly less use in those receiving 16mg of buprenorphine plus 4mg of naloxone, versus placebo. However, there was no difference in the lower dose (4 mg buprenorphine plus 1 mg naloxone). The strength of evidence was insufficient.^34^ See Table 7 for study-level data and Conclusions Table B for a summary of findings.

Table 7 Trials to treat cocaine use disorder using pharmaceuticals prescribed for other substance use disorders

Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Abstinence, Lapse or Relapse: ≥2 weeks, N (%) or longest consecutive period/time to relapse, mean (SD) | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
Disulfiram
Carroll, 2012^21^ Single site - US N=112 12 wks | 59 vs 53 Disulfiram 250mg/day dissolved in methadone 12 wks 12-step facilitation weekly vs. standard counseling sessions UA 3x weekly | Subgroup: Opioid, EtOH 59% Male Race: 22% AA, 64% white SES: NR | NR | NR | 76% who initiated T completed full course. P=ns | WD: 1 SAE: None | Low
Carroll, 2016^20^ single site - US N=99 12 wks | 51 vs 48 Disulfiram 250mg/day 12 weeks CBT +/− CM UA 3x/wk | Subgroup: EtOH Male: 74% Race: 49.5% AA SES: NR | 13/51 (25.5%) vs 11/48 (22.9%) | NR | F test 3.13, p=.08 Favors disulfiram | NR | Low
Oliveto, 2011^40^ 2 sites - US N=155 12 wks | 3 arms: 37/38/39 vs 38, Disulfiram 62.5mg/125mg/250mg daily Methadone maintenance and weekly CBT UA 3x/wk | Subgroup: Opioid Male: 48.7% Race: White 78%; AA 10.5% SES: NR | NR | UA(-): 391/1810 (21.6%) vs 159/449 (35.4%) P<.05 | 72/116 (62.1%) vs 29/39 (74.4%) P=ns | WD: 6 No severe AE reported | Low
Schottenfeld, 2014^52^ single site - US N=177 12 wks | 91 vs 86 Disulfiram 250mg, 6 days/wk 12 wks Buprenorphine 16mg/day Weekly manual guided group drug counseling UA 3x/wk | Subgroup: Opioid Male: 71.8% Race: 69% White SES: NR | abstinence ≥3 wks: 18% vs 21% P=0.57 | Mean (SD) UA(-) samples: 10.7 (11.5) vs 10.0 (11.4), P=ns | 43/91 (47%) vs 49/86 (56.9%) | WD: 8 due to SAE | Low
Kosten, 2013^31^ 2 sites - US N=74 12 wks | 34 vs 40 Disulfiram 250mg/day 12 wks Methadone maintenance and weekly CBT UA 3x/wk | Subgroup: Opioid Male: 64.9% Age: 39 Race: NR SES: NR | NR | NR | 77% vs 87% No significant difference | WD: 6 SAE: 4 | Low
Naltrexone
Hersh, 1998^23^ single site - US N=64 8 wks | 31 vs 33 50mg NTX/day 8 wks Individual relapse prevention psychotherapy 12/wk UA 2x/wk | Subgroup: EtOH Male: 93.5% Age: 35.2(6.0) Race: 77.5% White | Time to relapse: 2.5 (2.8) wks vs 2.1 (2.4) wks Difference not significant | NR | NR | WD: 1/31 (3.2%) vs 2/33 (6%), P=ns Severe AE: 2/31 (6.5%) vs 11/33 (33.3%) P=0.097 | Low
Pettinati, 2008^43^ Single site - US N=164 12 wks | 82 vs 82 150mg/day naltrexone 12 wks CBT - 45 min/wk vs BRENDA (a type of medical management) - 30 min/wk UA 1x/wk | Subgroup: EtOH, gender Male: 70.8% Age: 39.1 (7.0) SES: NR | NR | NR | 55/82 (67%) vs 50/82 (61%), P = ns | NR | Unclear
Pettinati, 2014^42^ Single site - US N=80 8 wks | 39 vs 41 One 380mg XR-NTX injection or placebo injection at randomization, and again at 4 weeks CBT 1x/week UA 3x/week | Subgroup: EtOH Male: 81.3% Age: 47.9 (6.6) Race: 87.5% AA/Black SES: NR | Abstinence ≥3 consecutive wks 17.9% vs 17.1% P = .918 | NR | 28/39 (72%) vs 34/41 (83% | WD: None SAE: 5/39 (12.8%) vs 4/41 (9.8%) P = ns | Low
Schmitz, 2004^51^ single site, US N=80 12 wks | 40 vs 40 naltrexone 50mg/day 12 wks Individual therapy sessions 1–2x/week UA 1x/week | Subgroup: EtOH Male: 83.7% Age: 35.9 (6.4) Race: 51.2% AA SES: NR | NR | No differences by medication; NOS | Overall 33% completed; no significant difference (p=0.47); NOS | NR | Low
Schmitz, 2009^50^ single site, US N=87 12 wks | 45 vs 42 Naltrexone 100mg/day 12 wks CBT vs CBT+CM UA 3x/week | Subgroup: EtOH Male: 87.3% Age: 34.41 (4.55) Race: 71.3% AA/Black SES: NR | NR | NR | 25 (33%) Ss completed treatment; No significant difference; NOS | NR | Low
Acamprosate
Kampman, 2011^28^ single site, US N=60 8 wks | 34 vs 26 Acamprosate 666mg 3x/daily 8 wks weekly individual CBT UA 2x/week | Subgroup: EtOH Male: 75% Age: 45 Race: 85% AA/Black SES: NR | NR | % UA (-): 22% vs 23% P=0.44 | 18/34 (53%) vs 18/26 (69%) | NR | Low
Varenicline
Plebani, 2012^44^ | 18 vs 19 2 mg/d 9 wks CBT 1x/wk UA 3x/wk | Male; 70% Age: Race: 89 vs 67% AA/Black (p<.03) SES: NR | NR | Trend toward lower use w varenicline: OR 0.495, (p = 0.08) | 77% with no significant difference in time to last visit (F=2.77, p = 0.10); not otherwise specified | NR | Unclear
Poling, 2010^45^ | 13 vs 18 2 mg/d 12 wks Methadone up to 140 mg/d CBT 1x/wk UA 3x/wk | Subgroup: tobacco and opioid dependent Male; 81% Age: 36.5 Race: 23% AA/Black, 13% Hispanic SES: 12.7y educ | NR | “No significant changes in slope for either group and these slopes do not differ from each other (Z = 0.20, p < 0.84).” | 5 subjects dropped out; no difference between groups (log rank χ^2^ = 1.3, p < 0.26); not otherwise specified | None occurred | Unclear
Opiate Agonists
Buprenorphine plus naloxone
Ling, 2016^34^ multi-site, US N=302 8 wks + 3 mo f/up | BUP 4mg + Nalox 1mg (N=100) vs Bup 16mg + Nalox 4mg (N=100) vs Placebo (N=100) All Ss received 380 mg XR-NTX injection at wks 1 & 5 Bup: naloxone tablets 4:1 mg/day vs 16:4 mg/day 8 wks UA 3x/week | Subgroup: Opioid Male: 78.4% Age: 46.4 Race: 63% AA/Black; 25.8% white SES: NR | 100% abstinent during weeks 5–8: BUP4 17/95 (17.9%) BUP16 18/97 (18.6%) Placebo 16/100 (16%) BUP4 vs Placebo, P=0.362 BUP16 vs Placebo, P=0.318 | UA(-): BUP4 50.4% BUP16 50.9% Placebo 45.8% BUP4 vs Placebo, P=0.105 BUP16 vs Placebo, P=0.022 | Retention defined as % who received 2nd XR-NTX injection at week 5: Placebo: 89/102 (87.3%) Bup4: 86/100 (86.0%) Bup16: 88/100 (88.0%) | NR | Low
Buprenorphine vs methadone
Schottenfeld, 1997^54^ single site, US N=116 24 wks | 4 groups (MTD65, Bup12, MTD20, Bup4): 28 vs 29 vs 30 vs 29 Buprenorphine 12mg or 4 mg or Methadone 65mg or 20 mg 24 wks 60 min group counseling 1x/wk UA 2–3x/week | Subgroup: Opioid Male: 69% Age: 32.6 Race: 70.7% White SES: NR | Abstinence ≥3 wks: 50.0% vs 34.5% vs 40.0% vs 20.7% P=0.14 | NR | Rates of Completion: 64.3% vs 55.2% vs 46.7% vs 34.5% P=.09 Combined doses: 41% vs 27.6%, P=ns | NR | Low
Schottenfeld, 2005^53^ 1 site, US N=162 24 weeks | 80 Methadone 35mg/d (40 CM, 40 PF) vs 82 Buprenorphine 4mg/d (39 CM, 43 PF) Manual guided counseling 2x/wk UA 3x/wk | Subgroup: Opioid Male: 66% Age: 36.2 (6.3) Race: 52% White; 36% AA/Black SES: NR | Max consecutive wks abstinence, mean (SD): MTD 5.5 (6.5) vs Bup 2.7 (4.7) P < .05 | % UA(-), mean (SD): MTD 45.2% (34.3%) vs Bup 29.3% (31.2%) P<.05 | 54/80 (67.5%) vs 38/82 (46.3%) P<.05 | SAE: 1 | Low

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AE = adverse event; AA = African American; BUP = Buprenorphine; C = control group; CBT = Cognitive Behavioral Therapy; CI = confidence interval; hr = hour(s); CM = contingency management; US = United States; MA = methamphetamine; mg = milligrams; MI = Motivational Interviewing; MTD = Methadone; NOS = Not otherwise specified; NR = Not reported; NS = not significant; OR = Odds ratio; P = p-value; PF = performance feedback; ROB = risk of bias; SAE = severe adverse event; SES = socioeconomic status; WD = withdrawal; wk = week; XR-NTX = Injectable Extended-Release Naltrexone

### Anticonvulsants and Muscle Relaxants

#### Anticonvulsants

##### Summary of Findings

One systematic review and 1 newer trial provide evidence on the use of anticonvulsants for cocaine use disorder. The systematic review found moderate strength of evidence for no overall effect for anticonvulsants on cocaine use and treatment retention. One newer RCT found significantly lower cocaine use with topiramate, although the strength of evidence is insufficient. We found a significant increase in continuous abstinence in studies of topiramate, though the strength of evidence is low owing to methodological limitations. The effect of vigabatrin on continuous abstinence was unclear based on 2 studies with low strength of evidence. A meta-analysis of treatment retention in topiramate trials found moderate strength evidence of no difference in study retention between topiramate and placebo.

##### Detailed Findings

One previous systematic review (15 RCTs; N=1066) of anticonvulsant drugs examined carbamazepine, gabapentin, lamotrigine, phenytoin, tiagabine, topiramate, and vigabatrin.^14^ The review found moderate strength of evidence of no effect on dropout (RR 0.95; 95% CI: 0.86 to 1.05) or cocaine use (RR 0.92; 95% CI: 0.84 to 1.02) outcomes for any anticonvulsant.^14^ In analyzing a single anticonvulsant versus placebo, they found no difference in dropout from treatment for any pharmacotherapy except gabapentin (significant difference favoring placebo [RR 2.78; 95% CI: 0.67 to 11.61]) and vigabatrin (favors treatment, although the results did not reach statistical significance [RR 0.74; 95% CI: 0.53 to 1.02]). For the cocaine use outcome there was no difference for any single pharmacotherapy versus placebo.^14^

##### Topiramate

Our search identified 1 additional, recent RCT of topiramate that showed promising abstinence (participants with all UA samples negative: P=0.002 for weeks 1–4 and 5–10, and P<.001 for weeks 11–12) and cocaine use results (the OR of obtaining a negative UA was 8.687; P<.001).^18^ Retention between groups was identical. While we determined the risk of bias to be low, the trial had a relatively small sample size (N=60).^18^ (See Table 8 for study-level data, and Conclusions Table C for a summary of findings). Because the systematic review did not examine continuous abstinence as an outcome we also analyzed continuous abstinence data for those RCTs included in the SR which reported this outcome. Two unclear-ROB RCTs^66,67^ examining topiramate provided low SOE of benefit (RR 2.56 [95% CI 1.39 to 4.73]) of topiramate for 2 or more weeks of continuous cocaine abstinence (see Figure 8a).

Figure 8a Abstinence for 2+ continuous weeks in RCTs of topiramate vs placebo for cocaine use disorder

We also performed a meta-analysis of the study retention outcome for topiramate combining the new RCT^18^ and 4 studies^67–70^ included in the previous systematic review.^14^ We found no difference in study retention between the topiramate and placebo groups; the combined OR for study completion was 1.13 (95% CI: 0.80 to 1.61). See Figure 8b for results.

Topiramate continues to be studied. One Phase II trial is under way studying the combination of Adderall-ER and topiramate for cocaine use disorder (NCT01811940). The results of this study were not available.

Figure 8b Retention in studies comparing topiramate vs placebo for cocaine use disorder

##### Vigabatrin

Aside from the aforementioned retention findings in the previous systematic review, we analyzed data on continuous abstinence from individual RCTs included in the review. Two RCTs (1 unclear-,1 high-ROB) found low strength of evidence for unclear effects on continuous abstinence (RR 2.35; 95% 0.92 to 5.98).^71,72^ These studies suffered from inconsistent findings and methodologic issues (incomplete data reported on continuous abstinence for the full trial period in both studies). See Figure 9 for details.

Figure 9 Abstinence for 2+ consecutive weeks in trials comparing vigabatrin vs placebo for cocaine use disorder

#### Muscle Relaxants

##### Summary of findings

From 2 trials we found low strength of evidence of no effect of baclofen on all outcomes of interest. There was no evidence for any other muscle relaxants.

##### Detailed findings

There is a paucity of evidence for the use of muscle relaxants for cocaine use disorder. No previous systematic reviews exist. We identified 2 trials of the muscle relaxant baclofen. One smaller study (N=70) was quality rated unclear for insufficient information reporting, and found no significant difference between groups on abstinence, cocaine use, or retention.^56^ The other trial was larger (N=160), and had better reporting, but did not take frequent enough urine samples (one time per week) to validate the abstinence findings.^26^ Cocaine use and retention findings were not significantly different.^26^ Overall, there is low strength of evidence for no effect on any outcomes of interest with the use of muscle relaxants. See Table 8 for study-level data and Conclusions Table C for a summary of findings.

We performed a meta-analysis of the treatment retention outcome across these 2 studies (N=230).^26,56^ One study enrolled 160 patients for 12 weeks,^26^ and the other study enrolled 70 patients with 20 weeks follow-up.^56^ Overall retention was much lower in the 20-week study (24.3% vs 71.9%), but in both studies there was no significant difference in retention between the treatment groups; the combined OR of study completion was 1.09 (95% CI 0.61 to 1.96). See Figure 10.

Figure 10 Retention in studies that compared baclofen vs placebo for cocaine use disorder

Table 8 Placebo-controlled trials of anticonvulsants/muscle relaxants for treating cocaine use disorder

Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Abstinence, Lapse or Relapse, UA-confirmed: ≥2 weeks, N (%) | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
Topiramate
Baldacara, 2016^18^ Single-site, outpatient (Brazil) N=60 12 wks follow-up | 30 vs 30 Topiramate (200 mg/day) 12 wks 8 motivational interviews + group therapy 1x/wk; UA 2x/wk | 100% Male Age: 28.6 (4.7) Race/SES: NR | N (%) with all UA(-) samples: Wks 1–4: 18 (60%) vs 6 (20%), P=.002 Wks 5–10: 19 (63.3%) vs 7 (23.3%), P=.002 Wks 11–12: 20 (66.7%) vs 4 (13.3%), P<.001 | OR of obtaining a UA(-) over 12 wks: 8.687, P<.001 | 58 completed study: 29/30 (96.7%) vs 29/30 (96.7%) | WD: None Severe AEs: None | Low
Baclofen
Kahn, 2009^26^ 8 sites, outpatient (US) N=160 12 wks follow-up | 80 vs 80 Baclofen (60mg/day) 8 wks 1 hr individual CBT weekly UA 1x/wk | 78.8% Male Age: 42.3 (8.2) Race: 24% White; 63.3% AA/Black Education yrs: 13.0 (2.1) Employment: NR | Longest abstinence, days: 6.1 (6.8) vs 7.4 (9.7), P=.37 | % who reduced use days to 75% or less of baseline rate: Baclofen 42.9, placebo 46.1, P= 0.75 % who reduced use days to 50% or less of baseline rate: Baclofen 15.6, Placebo 19.2, P=0.67 | 115 completed study: 58/80 (72.5%) vs 57/80 (71.3%) P=0.84 | WD: NR Severe AEs: 3 (3.75%) vs 6 (7.5%) | Unclear; UA frequency not clearly specified
Shoptaw, 2003^56^ Single-site, outpatient (US) N=70 20 wks follow-up | 35 vs 35 Baclofen 20mg/day 16 wks CBT group counseling 3x/wk UA 3x/wk | 68.57% Male Age: 34.03 (6.4) Race: 20% White, 40% AA/Black Education yrs: 12.83 (2.5) Employment: days worked in month prior: 10.11 (9.8) vs 12.5 (13.1) P= 0.04 | N (%) with 3 consecutive wks abstinence: 6 (17.14) vs 4 (11.43), P=ns Longest abstinence, days: 11.81 (17.7) vs 11.06 (21.5), P=ns | % of UA(-) samples, mean (SD): 64.23 (36.3) vs 52.44 (40.4), P=ns | 17 completed study: 9/35 (25.7%) vs 8/35 (22.9%), P=ns | WD: 1 (2.9%) vs 0 Severe AEs: 3 (8.6%) vs 0 | Unclear; insufficient information reported

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AA = African American; AE = adverse event; C = control group; CBT = Cognitive Behavioral Therapy; CI = confidence interval; hr = hour(s); US = United States of America; MA = methamphetamine; mg = milligrams; NR = not reported; NS = not significant; OR = odds ratio; P = p-value; ROB = risk of bias; SD = standard deviation; SES = socioeconomic status; sig = statistically significant; T = treatment group; UA = urinalysis; WD = withdrawal; wk(s) = week(s); yrs = years

### Dopamine Agonists

A 2015 systematic review of 24 trials found no differences between any dopamine agonist and placebo on retention (moderate SOE), abstinence (low SOE), or adverse events (moderate SOE).^13^ See Conclusions Table D for a summary of findings. Our search did not yield any recent trials of dopamine agonists for cocaine use disorder.

### Other Pharmacotherapies

Nineteen additional studies examined the effects of other drugs or drug combinations for cocaine use disorder. Positive findings on abstinence and use reduction were reported in studies of doxazosin,^57^ ondansetron,^24^ propranolol,^29^ and topiramate combined with mixed amphetamine salts.^38^ As there was only one study on each of these medications, the strength of evidence for each is considered insufficient. Studies of amlodipine, carvedilol, celecoxib, citicoline, cocaine-metabolizing fusion protein TV-1380 (AlbuBChE), D-cycloserine, dehydroepiandrosterone (DHEA), galantamine, ginkgo biloba, magnesium L-aspartate hydrochloride, mecamylamine, metyrapone combined with oxazepam, N-acetylcysteine, pioglitazone, piracetam, and progesterone found no benefit on study retention, use, or abstinence.^22,25,27,30,32,33,35,37,38,47–49,55,58–60^

### Pharmacotherapies for Comorbid Cocaine and Opioid Use Disorders

#### Antidepressants

##### Summary of Findings

Data from 3 systematic reviews contribute to the evidence examining antidepressants (desipramine, fluoxetine, bupropion) for the treatment of cocaine use disorder in adults with comorbid opioid use disorder.^5,11,16^ In general, there were very few high-quality studies, and a good number of studies were underpowered. As a class, there is low strength evidence that antidepressants are more effective than placebo for sustained abstinence.^11^ There is moderate strength evidence that antidepressants are less effective than placebo for study retention and treatment withdrawals due to adverse events.^16^ Although the evidence is insufficient due to small samples and quality concerns, studies in the systematic reviews reported that both desipramine^11^ and bupropion^5,11^ were more effective than placebo for sustained cocaine abstinence. There is moderate strength evidence that desipramine has no benefit for study retention, low strength evidence of no benefit of both fluoxetine and bupropion on retention, and low strength evidence of no difference between desipramine and placebo for treatment withdrawals due to adverse events.^16^

##### Detailed Findings

Evidence examining antidepressants for the treatment of cocaine use disorder in adults with comorbid opioid use disorder comes from 2 systematic reviews.^5,16^ 3 RCTs^65,73,74^ in a systematic review^11^ contribute to low strength evidence that antidepressants are more effective than placebo for sustained abstinence (N=183; combined RR 1.82 [95% CI 1.19 to 2.78]; see Figure 11). There is moderate strength evidence that antidepressants are less effective than placebo for study retention (10 RCTs, N=1,006; combined RR 1.22 [95% CI 1.05 to 1.41]) and treatment withdrawals due to adverse events (5 RCTs, N=492; combined RR 2.47 [95% CI 1.03 to 5.90]).^16^ Only 1 unclear-ROB study, included in both systematic reviews, examined cocaine use during the trial period, and found no difference between antidepressants and placebo (see Conclusions Table E for a summary of findings).^5,11^

Figure 11 Abstinence in studies of antidepressants vs placebo in patients with dual opioid and cocaine use disorders

##### Tricyclic Antidepressants: Desipramine

Findings from 2 systematic reviews provide evidence examining desipramine for the treatment of cocaine use disorder in adults with comorbid opioid use disorder.^11,16^ Two small, underpowered RCTs^73,74^ in a systematic review^11^ found that desipramine was more effective than placebo for sustained cocaine abstinence (N=78; combined RR 2.73 [95% CI 1.20 to 6.21]; see Figure 12); however the strength of evidence is insufficient due to the small sample and population heterogeneity. Six RCTs in a systematic review provide moderate strength evidence that desipramine is less effective than placebo for study retention (N=544; combined RR 0.86 [95% CI 0.74 to 0.99]), and the same review included 3 RCTs that provided low-strength evidence that desipramine is similar to placebo on treatment withdrawals due to adverse events (N=157; combined RR 1.66 [95% CI 0.35 to 7.96]).^16^ We identified no evidence comparing desipramine to placebo on rates of severe adverse events in adults with comorbid cocaine and opioid use disorders (see Conclusions Table E for a summary of findings).

Figure 12 Abstinence in studies of desipramine vs placebo in patients with dual opioid and cocaine use disorders

Note. Poling, 2006^65^ which examines bupropion is listed, but data are not included in the combined risk ratio.

##### Selective Serotonin Reuptake Inhibitors: Fluoxetine

Two (1 low-, 1 high-ROB) RCTs in a systematic review provide evidence examining fluoxetine for the treatment of cocaine use disorder in adults with comorbid opioid use disorder.^16^ Both RCTs in the review provide low strength evidence that fluoxetine has no benefit over placebo for study retention, and a single low-ROB RCT provides insufficient evidence that treatment withdrawals due to adverse events may be greater in those receiving fluoxetine. No other outcomes of interest were reported (see Conclusions Table E for a summary of findings).

##### Bupropion

Two (1 unclear-, 1 high-ROB) RCTs in 2 systematic reviews provide evidence examining bupropion for the treatment of cocaine use disorder in adults with comorbid opioid use disorder.^5,16^ One unclear-ROB RCT included in both reviews examined both cocaine use and sustained cocaine abstinence. Findings indicate better rates of sustained abstinence in participants receiving bupropion; however, there was no difference in study period cocaine use (SOE insufficient). Both RCTs contribute to low strength evidence of no difference between bupropion and placebo for study retention, and 1 high-ROB RCT provides insufficient evidence of similar rates of treatment withdrawals due to adverse events (see Conclusions Table E for a summary of findings).^16^

#### Antipsychotics

##### Summary of Findings

Evidence on the effectiveness of antipsychotics (aripiprazole, risperidone) for the treatment of cocaine use disorder in adults with comorbid opioid use disorder comes from a systematic review^12^ and 1 very small RCT.^39^ Findings indicate no difference between aripiprazole and placebo for cocaine use during the trial period, prevention of lapse and relapse, retention, and harms in participants abstinent at baseline, and no difference between risperidone and placebo for retention (SOE insufficient for all outcomes).

##### Detailed Findings

##### Aripiprazole

Evidence on the effectiveness of aripiprazole for the treatment of cocaine use disorder in adults with comorbid opioid use disorder comes from a systematic review^12^ and 1 very small RCT.^39^ The high-ROB RCT^39^ compared aripiprazole to placebo, along with contingency management and individual counseling in methadone-maintained adults. Participants first went through a 12-week methadone stabilization phase that included contingency management and (unspecified) treatment, and those who achieved cocaine abstinence in weeks 11 and 12 were randomized to 15mg of aripiprazole or placebo (N=18), with contingency management continuing through the 2-week induction phase. Time to both lapse (first cocaine-positive urine sample; HR=0.45, 95% CI [0.14 to 1.42], P=0.17) and relapse (2 consecutive cocaine-positive urine samples or missed urines; (HR= 0.31, 95% CI [0.07 to 1.27], P=0.10) were similar between groups, and there was no difference in the longest duration of abstinence, retention, or harms. The study was discontinued early due to the small number of participants (18 of 41 enrolled) able to achieve abstinence in weeks 11 and 12 (see Table 9 for study details and Conclusions Table E for a summary of findings).

##### Risperidone

One unclear-ROB RCT in a systematic review provides insufficient evidence of no difference between risperidone and placebo on study retention.^12^ No other outcomes of interest were reported (see Conclusions Table E for a summary of findings).

Table 9 Trials of antipsychotics for treating cocaine use disorder in patients with comorbid opioid use disorder

Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Time to lapse and relapse, UA-confirmed | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
ATYPICAL ANTIPSYCHOTIC: Aripiprazole
Moran, 2017^39^ 1 site (US) N=18 (41 enrolled) All participants were abstinent at baseline 41 wks follow-up | 9 vs 9 Aripiprazole 15mg/day (MTD) 12 wks CM during 2-week induction UA 3x /wk | 94% Male Age: 46 Race: 12.5% White, 81% AA/Black Education: 12.5 yrs Unemployed: 12.5% | M (SEM) longest duration of abstinence: 20.11 (4.87) vs 14.89 (4.19), P = 0.43 There was no difference in time to lapse (HR = 0.51, 95% CI [0.18, 1.48], P = 0.21]. There was no difference in time to lapse. | M% (SEM) of UA (-) samples: 58% (12%) vs 55% (11%), P = 0.66 | 14 completed study: 8 (89%) vs 6 (67%) | WD: 0 (0%) vs 1 (11%) Severe AEs: NR | High

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AE = adverse event; AA = African American; C = control group; CBT = Cognitive Behavioral Therapy; CI = confidence interval; hr = hour(s); CM = contingency management; US = United States of America; MA = methamphetamine; mg = milligrams; MI = Motivational Interviewing; MTD = maximum tolerated dose; NR = Not reported; NS = not significant; OR = Odds ratio; P = p-value; ROB = risk of bias; SD = standard deviation; SEM = standard error of the mean; SES = socioeconomic status; sig = statistically significant; T = treatment group; TTM = Transtheoretical Model; UA = urinalysis; wk(s) = week(s); yrs = years.

#### Psychostimulants

##### Summary of Findings

Evidence related to the effectiveness of psychostimulants (dexamphetamine, mazindol) for the treatment of cocaine use disorder in adults with comorbid opioid use disorder comes from 2 systematic reviews.^5,11^ There is low strength evidence that psychostimulants as a class are more effective in preventing cocaine use during studies^11^ and that there is no difference between psychostimulants and placebo for sustained abstinence^11^ and retention.^5^ One RCT in a systematic review found that dexamphetamine was more effective than placebo for sustained cocaine abstinence (SOE insufficient).^5^ There were no differences across other outcomes for both dexamphetamine and mazindol.

##### Detailed Findings

Two systematic reviews provide evidence related to the effectiveness of psychostimulants (dexamphetamine, mazindol) for the treatment of cocaine use disorder in adults with comorbid opioid use disorder.^5,11^ Pooled findings from three (2 unclear-, 1 high-ROB) RCTs^75–77^ in the review provide low strength evidence both that psychostimulants as a class are more effective in preventing cocaine use during trials (N=115; SMD 0.35 [95% CI −0.05 to 0.74] see Figure 13).^11^ Two (1 unclear-, 1 high-ROB) RCTs^75,76^ in the systematic review provide pooled evidence of no difference between psychostimulants and placebo for sustained cocaine abstinence (see Figure 14).^11^ No difference was reported for study retention (1 unclear-, 2 high-ROB RCTs; see Conclusions Table E for a summary of findings).^5^

Figure 13 Cocaine-free UA samples in studies of psychostimulants vs placebo in patients with dual opioid/cocaine use disorder

Figure 14 Abstinence in studies comparing psychostimulants vs placebo in patients with dual opioid/cocaine use disorders

##### Dexamphetamine

One high-ROB RCT^75^ included in 2 systematic reviews^5,11^ provides evidence examining the use of dexamphetamine for the treatment of cocaine use disorder in adults with comorbid opioid use disorder. There is insufficient evidence suggesting that dexamphetamine may be more effective than placebo in the achievement of sustained cocaine abstinence (N=94; RR 2.54 [95% CI 1.22 to 5.30]).^5,11^ No differences were found for cocaine use during the trial period (N=61; SMD 0.26 [95% CI −0.29 to 0.80])^11^ or retention (N=94; RR 1.78 [95% CI 0.96 to 3.29])^5^ (SOE insufficient). No evidence related to harms was reported (see Conclusions Table E for a summary of findings).

##### Mazindol

Two small, unclear-ROB RCTs^76,77^ included in 2 systematic reviews^5,11^ provide insufficient evidence examining the use of mazindol for the treatment of cocaine use disorder in in adults with comorbid opioid use disorder. One small unclear-ROB RCT found no difference in sustained cocaine abstinence (N=37; RR 1.06 [95% CI 0.62 to 1.80]),^11^ and 2 underpowered unclear-ROB RCTs found no difference on cocaine use (N=54; SMD 0.44 [95% CI −0.12 to 1.01]; see Figure 15)^11^ and study retention (see Conclusions Table E for a summary of findings).^5^

Figure 15 Cocaine-free UA samples in studies of psychostimulants (Mazindol) vs placebo in patients with dual opioid/cocaine use disorder

#### Anticonvulsants

##### Summary of Findings

In a previous systematic review, a meta-analysis of 2 trials of the GABAergic drugs tiagabine and gabapentin found no difference in abstinence.^11^ The combined RR was 1.02 (95% CI 0.56 to 1.89).^11^

#### Varenicline

An unclear-ROB study conducted in 31 patients with dependence on multiple substances (cocaine, tobacco, and opioids) reported no differences in retention between varenicline and placebo, or cocaine use throughout the study.^45^ See Conclusions Table F for a summary of findings.

## Key Question 2 Are there known subpopulations for whom different forms of pharmacotherapy is most/least effective for cocaine use disorder?

### Summary of Findings

We identified 11 RCTs and 1 systematic review that examine subgroup differences in adults with cocaine use disorder. Included subgroups are: cocaine severity at baseline,^23,56^ cocaine abstinent or negative at baseline,^19,46^ gender,^19,43,62^ comorbid or lifetime alcohol use disorder,^19–21^ comorbid opioid use disorder,^39^ cannabis use,^56^ comorbid ADHD,^5^ comorbid depression,^46^ and genetic variations.^78,31^

Overall, findings are inconclusive due to the limited number of studies examining each subpopulation and are hampered by the methodological issues frequently observed in studies of this population. However, it is possible that baclofen and naltrexone may be particularly effective when treating chronic/long-term cocaine users.^23,56^ In addition, the ability to achieve abstinence or produce a cocaine-negative urine sample may be a good predictor of treatment success^19,46^; certain drug therapies such as buspirone and naltrexone may have a lesser,^43^ or even a negative effect in women than in men^62^; adults with comorbid depression who experience a clinically significant mood response to venlafaxine may experience better results^46^; and chronic heroin users may benefit from a combination of methadone and aripiprazole.^39^ Findings suggest no differences in effect by self-reported cannabis use,^56^ the presence of alcohol use disorder^19–21^ or ADHD,^5^ and it is possible that genetic variations may play a role in treatment response.^78^

### Findings by Subpopulation

#### Cocaine Severity at Baseline

Two RCTs examined differences in cocaine use by cocaine addiction severity at baseline.^23,56^ Trials examined included baclofen^56^ and naltrexone^23^ in combination with CBT. In both studies, participants who were more severely addicted at baseline experienced greater benefit from the treatment, as compared to control. For participants receiving baclofen, baseline severity of cocaine use was positively related to a reduction in cocaine use over the study period (P=.001), with more severe use at baseline significantly associated with a greater reduction in use. In addition, findings indicate that although baclofen was more effective than placebo for a reduction in cocaine-positive UAs for the full sample, the greatest benefit was experienced by participants who presented with patterns of chronic use.^56^ Findings for naltrexone indicate a non-significant trend favoring naltrexone over placebo in the increase of cocaine-negative UAs for heavy users. No such trend was identified for the full sample (see Table 10 for more detail).^23^

#### Cocaine Abstinent or Negative at Baseline

Two RCTs examined differences in the effect of pharmacotherapy by baseline abstinence.^19,46^ Trials examined memantine^19^ and venlafaxine^46^ in combination with relapse prevention therapy. One study compared differences in participants who achieved abstinence during a 2-week placebo lead-in,^19^ and the other reported differences by the baseline cocaine UA.^46^ Neither study found a significant interaction between the treatment and cocaine abstinence or negative UAs; however, participants who had achieved abstinence or who provided a negative sample at baseline had more study period cocaine-negative UAs^19,46^ and a higher rate of achieving sustained abstinence,^19^ regardless of condition. No difference was found for study retention (see Table 10 for more detail).

#### Gender

Three RCTs examined the differential impact of gender on pharmacological treatments for cocaine use disorder.^19,43,62^ Trials examined naltrexone,^43^ buspirone,^62^ and memantine.^19^ One RCT,^62^ which compared buspirone to placebo in abstinent adults, found that although there was no benefit of buspirone on outcomes of interest in the full sample, women receiving buspirone experienced an increase in cocaine use (χ^2^ [1]=6.06, P=0.01) early in the study. In addition, there was a nonsignificant trend for a shorter time to lapse in women receiving buspirone (χ^2^[1]=3.20, P=.067). No such relationship was identified for men. The second RCT,^43^ that compared naltrexone to placebo found a significant difference in the rates of increase of cocaine use by gender (Z=2.21, P = 0.03). For men with comorbid alcohol and cocaine use disorders, 150mg/day of naltrexone was more effective than placebo. However, in women naltrexone was less effective. Finally, in a RCT comparing memantine to placebo,^19^ there was no difference in cocaine-negative samples by gender during the study, and the interaction between treatment and gender was nonsignificant (see Table 10 for more detail).

#### Comorbid or Lifetime Alcohol Use Disorder

Three RCTs examined the differential effect of pharmacological treatments for cocaine use disorder in adults with and without comorbid or lifetime alcohol use disorder.^19–21^ Two RCTs compared disulfiram to placebo,^20,21^ 1 in conjunction with CBT and CM,^20^. Neither trial found a difference between disulfiram and placebo for cocaine use in the full sample. However, when analyses were limited to participants with alcohol use disorder, 1 study found that disulfiram was more effective than placebo (t=4.26, P=.04), and the other did not.^20^ The third RCT^19^ compared memantine to placebo, and found no difference in cocaine-negative urine samples during the study, and the interaction between treatment and alcohol use disorder was nonsignificant (see Table 10 for more detail).

#### Comorbid Opioid Use Disorder

One underpowered RCT^39^ comparing aripiprazole to placebo in adults with comorbid opioid use disorder explored differences in outcomes by years of heroin use. The study found that years of heroin use was positively related to a longer time to lapse, with a nonsignificant trend for time to relapse. There was no difference in frequency of lapse by years of heroin use (see Table 10 for more detail).

Six of the 7 included trials of disulfiram for cocaine use disorder were conducted in subjects with comorbid opioid dependence.^21,31,40,52,63,64^ The findings in KQ1 for disulfiram therefore largely reflect the experience of this subpopulation.

Subjects with comorbid opioid disorder randomized to disulfiram had lower retention compared with placebo (moderate SOE), and the combined estimate became slightly more significant (RR 0.88, 95% CI 0.79 to 0.98) upon excluding the only study conducted in non-opioid dependent subjects.^20^

Abstinence was similar between disulfiram and placebo in two studies^52,63^ of patients with comorbid opioid disorder (combined N = 197; low SOE). Statistical heterogeneity between the two studies was not significant for this outcome (P=0.73).

The effects of disulfiram on overall cocaine use were significantly heterogeneous (P<.00001) among the 3 studies in patients with comorbid opioid disorder that reported this outcome (insufficient SOE).^21,31,40^

#### Cannabis Use

One RCT^56^ that compared baclofen to placebo examined differences between participants who self-reported cannabis use at baseline to those who did not. No difference in cocaine-negative urine samples during the trial was identified (see Table 10 for more detail).

#### Comorbid Attention Deficit Hyperactivity Disorder

A systematic review of 26 RCTs examining psychostimulants (including bupropion) for cocaine use disorder^5^ performed subgroup analyses comparing studies with and without comorbid ADHD as a requirement for inclusion. They found no significant differences between participants with and without ADHD on any outcome of interest (see Table 10 for more detail).

#### Comorbid Depression

One RCT^46^ that compared venlafaxine to placebo along with weekly CBT in adults with comorbid depression and cocaine use disorder, examined whether there were differences in cocaine response by mood response. Although they found no significant interaction between mood response and treatment condition, participants who experienced a clinically significant mood response had more cocaine-negative urine samples during the study (P < 0.0068). In addition, mood responders achieved 3 or more weeks abstinence at a higher rate than non-responders, although the trend was not significant (P=0.07; see Table 10 for more detail).

#### Genetic Variations

One RCT^78^ comparing disulfiram to placebo evaluated the role of the ADRA1A gene polymorphism on cocaine-negative urine samples by comparing individuals with at least one T allele of rs1048101 (TT or TC) to those who are homozygous (CC). The study found that for participants with the TT/TC genotype, disulfiram was more effective than placebo for cocaine-negative samples during the study (F=17.1, df=1.358; P<0.00005). There was no difference between disulfiram and placebo for those with the CC genotype.

Another RCT^31^ that compared disulfiram to placebo examined the role of the dopamine B-hydroxylase (DBH) gene polymorphism, which reduces DBH enzyme levels, on increasing cocaine-free urines with disulfiram. Participants were divided into two DBH genotype groups: those with a T allele of rs1611115 (CT/TT genotype) to those who were homozygous (CC genotype). The study found that those with normal levels of DBH (CC) had more cocaine-positive urines (F=17.2, P<.00005) than those with lower levels of DBH (CT/TT) (F=1.12, P>.05). See Table 10 for more detail.

Table 10 Subgroup analyses in studies of pharmacotherapy for cocaine use disorder, stratified by population characteristic

Study | N, T vs C Dose and duration Concomitant Tx UA frequency | Abstinence, Lapse, Relapse | Use | Retention | Summary of findings
Cocaine Severity at Baseline
Shoptaw 2003^56^ | 35 vs 35 Baclofen 20mg/day 16 wks CBT group counseling 3x/wk UA 3x/wk | NR | For participants receiving baclofen, baseline cocaine use was positively related to a reduction in cocaine use over the study period (P=.001), with more severe use at baseline significantly associated with a greater reduction in use. There was no relationship between baseline severity and use in participants receiving placebo. | NR | Baseline severity was positively related to greater reductions in cocaine use for participants assigned to baclofen, but not placebo.
Hersh 1998^23^ | 31 vs 33 50mg NTX/day 8 wks Individual relapse prevention psychotherapy 1–2/wk UA 2x/wk | NR | In participants with higher pre-treatment cocaine use, there was a nonsignificant trend favoring naltrexone for study period negative UAs (P=0.082). | NR | In participants with higher pre-treatment cocaine use, there was a nonsignificant trend favoring naltrexone for study period negative UAs.
Cocaine Abstinent or Negative at Baseline
Bisaga, 2010^19^ 1 site (US) Baseline N=81, Abstinent at Baseline N=36 16 wks follow-up | Memantine 40 mg/day 12 wks 2 wk placebo lead-in prior to randomization CM (wks 1–4), MET (wks 1–4), 1x/wk relapse prevention therapy (CBT) UA 3x/wk | No difference between memantine and placebo on abstinence. The interaction between treatment and baseline abstinence was nonsignificant. However, more participants who were abstinent at baseline achieved sustained abstinence (P = 0.01). | Participants who were abstinent at baseline had more cocaine-negative urine samples during the study (P < 0.0001); however, the interaction between treatment and baseline abstinence was nonsignificant. | There was no difference in retention by baseline abstinence. | Ss abstinent at baseline achieved sustained abstinence more frequently and had more cocaine-negative urine samples; however, the interaction between treatment and baseline abstinence was nonsignificant. No relationship between baseline abstinence and study retention.
Raby, 2014^46^ 1 site (US) N=130 12 wks follow-up | 64 vs 66 Venlafaxine Up to 300 mg/day 12 wks 1x/wk individual relapse prevention therapy (CBT, MI) UA 2x/wk | NR | Participants who were provided a cocaine-negative UA at baseline had more cocaine-negative urine samples during the study (P<0.0001); however, the interaction between treatment and baseline abstinence was nonsignificant (P=0.87) | NR | Participants who were abstinent at baseline had more cocaine-negative urine samples during the study; however, the interaction between treatment and baseline abstinence was nonsignificant
Gender
Bisaga, 2010^19^ 1 site (US) Baseline N=81 (79% Male) 16 wks follow-up | Memantine 40 mg/day 12 wks 2 wk placebo lead-in prior to randomization CM (wks 1–4), MET (wks 1–4), 1x/wk relapse prevention therapy (CBT) UA 3x/wk | NR | There was no difference in cocaine-negative samples by gender during the study, and the interaction between treatment and gender was nonsignificant. | NR | There was no difference in cocaine-negative samples by gender during the study, and the interaction between treatment and gender was nonsignificant.
Winhusen, 2014^62^ 6 sites (US) N=62 (63% Male) 12–19 days residential, remaining outpatient 16 wks follow-up | 35 vs 27 Buspirone 60 mg/day or MTD 15 wks CM Inpatient/residential (psychosocial TAU, Outpatient TAU (min of 60 min 1x/wk individual or group psychosocial treatment) UA 1x/wk | In women but not men, there was a nonsignificant trend for a shorter time to lapse in participants receiving buspirone (c2=3.20, P=.067). | In women but not men, there was an increase in cocaine use by participants receiving buspirone early in the outpatient treatment phase (c2=6.06, P=0.01). | NR | There was no benefit of buspirone on outcomes of interest in the full sample. However, buspirone may increase cocaine use and may result in a shorter time to lapse in women but not men.
Pettinati, 2008^43^ (N=116 men, N=48 women) | 82 vs 82 150mg/day naltrexone 12 wks CBT - 45 min/week; vs BRENDA- 30 min, weekly-manualized psychosocial intervention. UA 1x/wk | NR | There were significant differences in the rates of increase of cocaine use by gender (Z=2.21, P = 0.03). For men with comorbid alcohol and cocaine use disorders, 150mg/day of naltrexone was more effective than placebo. However, in women naltrexone was less effective. | NR | For men with comorbid alcohol and cocaine use disorders, 150mg/day of naltrexone was more effective than placebo. However, in women naltrexone was less effective.
Comorbid or Lifetime Alcohol Use Disorder
Bisaga, 2010^19^ 1 site (US) Baseline N=81, Abstinent at Baseline N=36 16 wks follow-up | Memantine 40 mg/day 12 wks CM (wks 1–4), MET (wks 1–4), 1x/wk relapse prevention therapy (CBT) UA 3x/wk | NR | There was no difference in cocaine-negative samples when comparing participants with and without comorbid alcohol use disorder, and the interaction between treatment and alcohol use disorder was nonsignificant. | NR | Comorbid alcohol use disorder was not related to differences in cocaine use during the study.
Carroll, 2012^21^ Alcohol use disorder N=70 Comorbid OUD population | 59 vs 53 disulfram 250mg/day 12 weeks 12-step facilitation weekly vs. standard counseling sessions UA 3x weekly | NR | There was no benefit of disulfiram on study period cocaine use over placebo for the full sample. However, when limited to participants with alcohol use disorder, disulfiram was more effective than placebo (t=4.26, P=.04). | NR | There was no benefit of disulfiram on study period cocaine use over placebo for the full sample. However, when limited to participants with alcohol use disorder, disulfiram was more effective than placebo.
Carroll 2016^20^ Alcohol use disorder N=74 | 51 vs 48 disulfram 250mg/day 12 weeks CBT +/− CM UA 3x/wk | NR | In both the full sample and in those with comorbid alcohol use disorder, disulfiram (with or without CM) had no effect on study period negative UAs. | NR | There were no differences between disulfiram and placebo for the full sample or for those with alcohol use disorders.
Comorbid Opioid Use Disorder: Years of Heroin Use
Moran, 2017^39^ N=18 (41 randomized) All participants were abstinent at baseline 41wks follow-up | 9 vs 9 Aripiprazole 15mg/day (MTD) 12 wks CM+ methadone + 1x/week individual counseling UA 3x /wk | Lapse: More years of heroin use was associated with longer latency to lapse (HR = 0.89 [95% CI 0.80 to 0.99], P < 0.05), but was not related to the risk of lapse (HR = 0.48 [95% CI 0.11 to 2.19], P = 0.35). Relapse: There was a nonsignificant trend towards years of heroin use as predictor of longer latency to relapse (P = 0.07). | NR | NR | Years of heroin use was positively related to a longer time to lapse, with a nonsignificant positive trend for time to relapse. There was no difference in frequency of lapse by years of heroin use.
Cannabis Use
Shoptaw 2003^56^ | 35 vs 35 Baclofen 20mg/day 16 wks CBT group counseling 3x/wk UA 3x/wk | NR | There was no relationship between self-reported cannabis use at baseline and cocaine-negative urine samples during the study. | NR | There was no relationship between self-reported cannabis use at baseline and cocaine-negative urine samples during the study.
Comorbid ADHD
Castells, 2016^5^ Systematic review of 26 RCTs | Psychostimulants (includes bupropion) | There was no difference between participants with comorbid ADHD (2 RCTs, N=232) and those without, in the achievement of sustained abstinence (P=0.11). | There was no difference between participants with comorbid ADHD (2 RCTs, N=154) and those without (6 RCTs, N=372) in cocaine-negative urine samples (P=0.21). | There was no difference between participants with comorbid ADHD (3 RCTs, N=180) and those without (21 RCTs, N=1,925) in retention (P=0.34). | There were no significant differences between participants with and without ADHD on any outcome of interest.
Comorbid Depression – Mood Responders
Raby, 2014^46^ 1 site (US) N=130 *Mood responder N=48, Mood non-responder N=82 12 wks follow-up | Venlafaxine 30 mg/day 12 wks 1x/wk individual relapse prevention therapy (CBT, MI) UA 2x/wk | There was a nonsignificant trend towards more participants who experienced a clinically significant mood response achieving 3+ week abstinence (P=0.07); however, the interaction between treatment and mood response was nonsignificant. | Participants who experienced a clinically significant mood response had more cocaine-negative urine samples during the study (P < 0.0068); however, the interaction between treatment and mood response was nonsignificant. | NR | Mood response was significantly related to fewer positive UAs. Although not significant, more mood responders achieved 3+ week abstinence.
Genetic Variations
Shorter, 2013^78^ ADRA1A genotype: TT or TC N=47, CC N=22 | Disulfiram 250mg/day 12 wks Methadone maintenance and weekly CBT UA 3x/wk | NR | For participants with the TT/TC genotype, disulfiram was more effective than placebo for cocaine-negative samples during the study (F=17.1, df=1.358; P<0.00005). There was no difference between disulfiram and placebo for those with the CC genotype. | NR | Disulfiram was more effective than placebo for cocaine-negative samples over the study period for participants with the TT/TC genotype, but not the CC genotype.
Kosten, 2013^31^ | Disulfiram 250mg/day 12 wks Methadone maintenance and weekly CBT UA 3x/wk | NR | Participants with the CC genotype dropped from 84% to 56% on disulfiram. Those with the CT/TT genotype showed no disulfiram effect. | NR | The DBH genotype of a patient could be used to determine the efficacy of disulfiram pharmacotherapy for cocaine use disorder.

Abbreviations: AA = African American; ADHD = attention deficit hyperactivity disorder; AE = adverse event; BBCET = Brief Behavioral Compliance Enhancement Therapy; CBT = Cognitive Behavioral Therapy; CI = confidence interval; HAM-D = Hamilton Depression Rating Scale; HIV = human immunodeficiency virus; P = p-value; MI = Motivational Interviewing; MTD = Methadone; NR = Not reported; P = p-value; RCT = randomized control trial; RR = Risk ratio; Ss = subjects; UA = urinalysis; US = United States

#### Subgroup Analysis of Contingency Management as a Co-intervention

In the substance use disorder literature there is evidence to support the effectiveness of contingency management (CM) in treatment retention.^79,80^ We examined whether the effectiveness of pharmacologic therapy differed according to whether patients were also receiving CM.

Among studies in patients with cocaine use disorder, 6 RCTs representing 4 drug classes provided CM to participants in all study arms.^19,36,39,41,61,62^ In 18 other studies,^17,18,21,23,26,28,31,34,40,42–46,50–52,54,56,78^ CM was not offered to any participants during the trial, of which 14 provided retention data. Retention among studies that offered CM to all participants was 59.3%, compared with 66.1% among studies that did not offer CM. Because of the variety of pharmacotherapies they used, these studies are not directly comparable.

Three multifactorial trials (representing 3 drug classes) directly compared use versus non-use of CM within active treatment and placebo groups.^20,50,53^ Only 2 of these studies provided retention data.^20,53^ Patients randomized to receive CM in these studies tended to be less likely to complete treatment compared to patients who did not receive CM (RR 0.91, 95% CI 0.79 to 1.05), although the combined estimate did not reach statistical significance (see Figure 16 for details). Because there were only 2 studies that directly examined the effects of CM, and the medications used in each study were not directly comparable, it is difficult to draw conclusions.

Figure 16 Retention in studies that directly compared CM(+) vs CM(−) in patients with cocaine use disorder

## Key Question 3 What are the benefits and harms of pharmacotherapy for Amphetamine/methamphetamine use disorder?

### Summary of Findings

We identified 14 RCTs and 1 systematic review that examined outcomes of interest of pharmacotherapy for amphetamine/methamphetamine use disorder. Pharmacotherapies examined included bupropion, mirtazapine, sertraline, aripiprazole, modafinil, dexamphetamine, methylphenidate, topiramate, baclofen, gabapentin, and naltrexone.

Similar to the body of research examining pharmacotherapy for cocaine use disorder, studies evaluating pharmacotherapy for amphetamine/methamphetamine use disorders were largely of low or unclear quality and underpowered. Co-interventions differed widely, and rates of retention varied greatly. Some studies examined methamphetamine or amphetamine use disorders exclusively, and others combined the two. For nearly all of the pharmacotherapies and almost all of the outcomes, findings were either null or insufficient to form conclusions. We identified only 1 pharmacotherapeutic for which there may be the potential for benefit. There is low strength evidence that methylphenidate may result in a reduction in use.

We identified only 1 unclear risk of bias RCT with a comorbid amphetamine/methamphetamine and opioid use disorder sample. Although the findings are insufficient from which to draw conclusions, the study found that naltrexone improved study retention.

### Antidepressants

#### Summary of Findings

One systematic review^81^ and 3 additional trials^82–84^ provide evidence on the use of antidepressants for methamphetamine use disorder. Overall, studies found no difference between antidepressants as a class over placebo for sustained abstinence (SOE low), study retention (SOE moderate), or severe adverse events (SOE low), and mixed findings related to methamphetamine use during the trial period. Similarly, no specific antidepressant (ie, sertraline, mirtazapine, bupropion) was found to have positive benefit over placebo on any outcome of interest.

#### Detailed Findings

One systematic review^81^ and 3 additional trials^82–84^ provide evidence on the use of antidepressants for methamphetamine use disorder. The systematic review^81^ focused on psychostimulants for methamphetamine use disorders; however, it included 6 RCTs of bupropion, which we classified as an antidepressant. One newer included trial also examined bupropion,^82^ and other trials examined mirtazapine,^84^ and sertraline.^83^

Findings from 3 RCTs in the systematic review^81^ (N=361; combined OR 1.12 [95% CI 0.54 to 2.33]) and one additional unclear-ROB RCT^83^ provide low strength evidence that antidepressants as a class are no different than placebo for the achievement of sustained abstinence. There is moderate strength evidence that antidepressants are not beneficial for study retention (based on 4 RCTs in the systematic review^81^ and 3 additional RCTs^82–84^), and low strength evidence that they are similar to placebo in treatment withdrawals due to adverse events (based on 1 unclear^82^ and 1 high-ROB RCT^84^). Findings related to methamphetamine use during the studies were mixed, with no benefit of antidepressants on use reported by the systematic review^81^ a modest, but non-significant trend favoring bupropion reported by 1 RCT,^82^ and findings of positive benefit reported in a small, high-ROB RCT^84^ (see Table 11 for study-level data and Conclusions Table G for a summary of findings).

##### Selective Serotonin Reuptake Inhibitors (SSRIs): Sertraline

A 12-week, unclear-ROB RCT (N=229)^83^ compared 100mg sertraline with and without contingency management (incentivizing negative urine screens) to placebo with and without continency management. All participants received 2 weeks of twice-weekly recovery skills group sessions, followed by 13 weeks of 90 minute thrice-weekly relapse prevention groups. When all 4 groups were compared, significantly fewer participants receiving sertraline alone achieved abstinence, (χ^2^[3] = 8.6, P = 0.035). When all participants receiving sertraline were compared to those receiving placebo, there was a strong trend favoring placebo (χ^2^[1] = 3.8, P = 0.052). In addition, participants receiving sertraline were retained for significantly less time than those receiving placebo (χ^2^[3] = 8.40, P < 0.05). No other outcomes of interest were examined (see Table 11 for study-level data and Conclusions Table G for a summary of findings).

##### Atypical Antidepressant: Mirtazapine

One small, 12-week, high-ROB RCT (N=60)^84^ compared 30mg of mirtazapine to placebo. Participants were men who have sex with men (MSM), and both groups received once-weekly individual substance use counseling. Findings indicate that participants who received mirtazapine had more negative UAs over the study period (RR 0.57; 95% CI [0.35 to 0.93], P = 0.02), but there was no difference in retention or severe adverse events (see Table 11 for study-level data and Conclusions Table G for a summary of findings).

##### Aminoketone: Bupropion

Four RCTs (1 unclear-, 3 high-ROB) in the systematic review^81^ and 1 unclear-ROB RCT from our search of primary studies provide evidence examining the use of bupropion for the treatment of methamphetamine use disorder. The RCT was an 18-week multi-site trial (N=151) comparing 300mg of bupropion to placebo.^82^ All participants received 90-minute CBT-relapse prevention group therapy 3 times per week. Results indicate no difference between bupropion and placebo on methamphetamine use during the studies, and a non-significant trend favoring bupropion in the rate of reduction (P=0.09). These findings, along with those of 3 high-ROB RCTs in the systematic review,^81^ provide low strength evidence of no difference between bupropion and placebo for reducing methamphetamine use. Combining the 5 RCTs provided moderate strength evidence that bupropion has no benefit over placebo for study retention (OR 1.10 [95% CI 0.73 to 1.67]). Three RCTs in the systematic review provide low strength evidence of no difference between bupropion and placebo on sustained abstinence (N=361; combined OR of 1.12 [95% CI 0.54 to 2.33]). There was no difference in reported severe adverse events (see Table 11 for study-level data and Conclusions Table G for a summary of findings).

Table 11 Placebo-controlled trials of antidepressants for treating methamphetamine use disorder

Setting Total N^*^ Mean follow-up | N, T vs C; Dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Abstinence, UA-confirmed ≥2 weeks, N (%) | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
AMINOKETONE: Bupropion
Elkashef 2008^82^ 5 sites (US) N=151 18 wks follow-up | 79 vs 72 Bupropion SR 300 mg/day 12 wks 90 min/3x weekly CBT-relapse prevention group UA 3x/wk | 67% male Age: 36 Race: 75% White, 3% AA/Black Education yrs: 12.5 Employment: NR | NR | N (%) week 12 UA (-): 42 (54%) vs 32 (44%) Modest trend for improvement over the treatment period (favors T), P = 0.09 Rate of reduction, P = 0.15 | 79 completed study: 41 (51.9%) vs 38 (52.8%) | WD: NR Severe AEs: 5 (6.3%) vs 8 (11.1%) | Unclear
ATYPICAL ANTIDEPRESSANTS: Mirtazapine
Colfax, 2011^84^ 1 site (US) N=60 12 wks follow-up | 30 vs 30 Mitrazapine 30 mg/day 12 wks 30 min 1x/week individual substance use counseling (CBT/MI) UA 1x/wk | 100%Male Age: 40.5 (9.0) Race: 62% White; 18% AA/Black Veteran/homeless: NR Education: 25% high school highest level of attainment Employment: 60% Unemployed | NR | N (%) week 12 UA (-): 18 (56%) vs 13 (37%). % of participants with UA (-) from baseline to week 12: 40% vs 6% UA (-) increased faster for T: RR = 0.57, 95% CI [0.35, 0.93], P = 0.02 | 56 completed study: 28 (93%) vs 28 (93%) | WD: NR Severe AEs: 1 (3%) vs 1 (3%) | High
SELECTIVE SEROTONIN REUPTAKE INHIBITOR (SSRI): Sertraline
Shoptaw, 2006^83^ 1 site (US) N=229 12 wks follow-up | T+CM = 61, T only = 59 vs P+CM = 54, P only = 55 Combined: 120 vs 109 Sertraline 100mg/day 12 wks CM + 2 wks of 60 min 2x/week recovery skills group, then 90 min/3x weekly CBT-relapse prevention group. UA 3x/wk | 62% male Age: 33 Race: 74% White, 0.4% AA/Black Education yrs: 12 Employment: 28% unemployed Severity: used 13 of last 30 days | N (%) 3 wk+ abstinent: 23 (43%) vs 15 (25%) vs 28 (59%) vs 23 (42%), P = 0.035 Collapsed to 2 groups: N (%) 3 wk+ abstinent: 41 (34%) vs 51 (48.6%), P = 0.052 | NR | 116 completed study: 31 (51%) vs 23 (39%) vs 29 (54%) vs 33 (60%) Collapsed to 2 groups: 54 (45%) vs 62 (57%) | WD: NR Severe AEs: NR | Unclear

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AE = adverse event; AA = African American; C = control group; CBT = Cognitive Behavioral Therapy; CI = confidence interval; hr = hour(s); CM = contingency management; US = United States of America; MA = methamphetamine; mg = milligrams; MI = Motivational Interviewing; NR = Not reported; NS = not significant; OR = Odds ratio; P = p-value; ROB = risk of bias; SD = standard deviation; SES = socioeconomic status; sig = statistically significant; SSRI = selective serotonin reuptake inhibitor; T = treatment group; TTM = Transtheoretical Model; UA = urinalysis; wk(s) = week(s); yrs = years.

### Antipsychotics

#### Summary of Findings

Two RCTs (1 unclear-ROB^85^ and 1 high-ROB^86^) provide evidence for the use of antipsychotics for the treatment of methamphetamine use disorder. Both trials compared aripiprazole to placebo and found no difference in sustained abstinence, use during the study, retention, or harms.

#### Detailed Findings

##### Second-generation Antipsychotic: Aripiprazole

Two RCTs provide evidence for the use of antipsychotics for the treatment of methamphetamine use disorder. One 12-week, unclear-ROB RCT (N=90) compared 20mg of aripiprazole to placebo.^85^ All participants received once weekly individual therapy (combination of CBT and MI). The second, a 20-week, high-ROB RCT (N=53) compared 15mg to placebo, with no concurrent interventions.^86^ Both studies contribute to low strength evidence of no difference between aripiprazole and placebo on methamphetamine use during trials. The evidence for all other outcomes of interest is insufficient, with neither study reporting a positive benefit associated with the use of aripiprazole (see Table 12 for study-level data and Conclusions Table G for a summary of findings).

Table 12 Placebo-controlled trials of antipsychotics (aripiprazole) for treating methamphetamine use disorder

Setting Total N^*^ Mean follow-up | N, T vs C; Dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Abstinence, UA-confirmed ≥2 weeks, N (%) | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
ATYPICAL ANTIPSYCHOTICS: Aripiprazole
Coffin, 2013^85^ 1 site (US) N=90 12 wks follow-up | 45 vs 45 Aripiprazole 20 mg/day (MTD) 12 wks 30 min/1x weekly individual psychotherapy (combination of CBT, MI) UA 1x/wk | 88% male Age: 38.7 (10.8) Race: 50% white, 19% AA/Black Education: 44% high school or less Employment: 74% unemployed | 8 (18%) vs 15 (33%), P = 0.15 | There was no difference in negative UAs, P = 0.41. | 75 completed study: 35 (78%) vs 40 (89%) | WD: 14 (31%) vs 3 (7%), P ≤ 0.01 Severe AEs: 6 total. | Unclear
Tiihonen, 2007^86^ NR sites (Finland) N=53 20 wks follow-up | 19 vs 17 Aripiprazole 15 mg/day 20 wks None UA 2x/wk | 68% male Age: 35.7 Race: 100% white SES: NR | NR | Positive UA, higher in T vs C (Adj OR = 3.77, 95% CI [1.55, 9.18], P = 0.003). | NR | WD: 2 (11%) vs 0 (0%) Severe AEs: 2 (11%) vs 0 (0%) | High

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AE = adverse event; AfrAm = African American; C = control group; CBT = Cognitive Behavioral Therapy; CI = confidence interval; hr = hour(s); CM = contingency management; US = United States of America; MA = methamphetamine; mg = milligrams; MI = Motivational Interviewing; MTD = maximum tolerated dose; NR = Not reported; NS = not significant; OR = Odds ratio; P = p-value; ROB = risk of bias; SD = standard deviation; SES = socioeconomic status; sig = statistically significant; T = treatment group; UA = urinalysis; wk(s) = week(s); yrs = years.

### Psychostimulants

#### Summary of Findings

A systematic review of 11 RCTs examined evidence for the use of psychostimulants (dexamphetamine, modafinil, methylphenidate) for the treatment of methamphetamine use disorder.^81^ Across all outcomes (sustained abstinence, use, retention, harms), there is low strength evidence that psychostimulants provide no benefit over placebo. The systematic review reported no benefit of either modafinil or dexamphetamine over placebo for any outcome of interest. There is low strength evidence of a positive effect of methylphenidate on methamphetamine use during studies. There was low strength evidence for no effect of methylphenidate on study retention.

##### Detailed Findings

Eleven RCTs in a systematic review provide evidence examining the use of psychostimulants (dexamphetamine, modafinil, and methylphenidate) for the treatment of methamphetamine use disorder.^81^ Four RCTs (N=278) in the systematic review provide low strength evidence of a positive effect of methylphenidate on methamphetamine use during the trial period. There is low strength evidence of no difference between methylphenidate and placebo for retention (5 RCTs in the systematic review; N=322). No differences were reported when comparing dexamphetamine or modafinil to placebo on any outcome of interest (SOE low).

##### Dexamphetamine

Findings come from 1 systematic review^81^ that included 2 RCTs (1 low, 1 unclear-ROB) examining dexamphetamine. There is low strength evidence of both no difference between dexamphetamine and placebo on methamphetamine use during trials, and no difference in study retention (combined OR 2.50 [95% CI 0.80 to 7.87]). No other outcomes of interest were examined (see Conclusions Table G for a summary of findings).

##### Methylphenidate

Six RCTs (1 low, 1 unclear, 4 high-ROB) in the systematic review^81^ examined methylphenidate for the treatment of methamphetamine use disorder. Three of 4 studies found participants receiving methylphenidate had significantly lower rates of methamphetamine use during the trial (low strength evidence). Five trials in the review (N=322) found no difference between groups for retention (combined OR 1.29 [95% CI 0.67 to 2.48]; SOE low). Of note, 2 of the trials examined individuals with amphetamine and not methamphetamine use disorder. Removing these trials does not change the findings of no difference. No other outcomes of interest were examined (see Conclusions Table G for a summary of findings).

##### Modafinil

Three RCTs in the systematic review^81^ examined modafinil for the treatment of methamphetamine use disorder. Two high-ROB RCTs in the review contribute to low strength evidence of no difference between modafinil and placebo for sustained abstinence (N=281; combined OR of 0.86 [95% CI 0.46 to 1.61]). Three RCTs (N=361; 1 unclear-, 2 high-ROB) found no difference in methamphetamine use during the trial period (SOE low) or retention (combined OR 1.00 [95% CI 0.64 to 1.55]; SOE low). No other outcomes of interest were reported (see Conclusions Table G for a summary of findings)

### Muscle Relaxants/Anticonvulsants

#### Topiramate

There are no previous systematic reviews of anticonvulsants for amphetamine/methamphetamine use disorder. We identified 1 moderately-sized (N=140), low-ROB trial of topiramate.^87^ There was a significant effect on use reduction greater than or equal to 25% of baseline median methamphetamine urine levels (P=0.03) as well as on use reduction greater than or equal to 50% (P=0.027). There was no difference in treatment retention, and the trial did not report on abstinence.^87^ There is low strength of evidence from this trial to support the use of topiramate for methamphetamine use disorder (see Table 13 for study-level data, and Conclusions Table H for a summary of findings).

#### Baclofen versus Gabapentin

There were no identified systematic reviews or trials addressing muscle relaxants for amphetamine/methamphetamine use disorder. We identified 1 smaller trial (N=88) which was a head-to-head comparing the muscle relaxant baclofen to anticonvulsant gabapentin or placebo.^88^ The trial was rated low risk of bias, and there was no statistically significant difference between groups in probability of providing negative urine drug screen (P=0.577), abstinence (P=NS), or retention (P=0.157).^88^ This does not offer sufficient strength of evidence to address whether muscle relaxants are an effective treatment for amphetamine/methamphetamine use disorder (see Table 13 for study-level data, and Conclusions Table H for a summary of findings).

Table 13 Trials of anticonvulsants/muscle relaxants for treating methamphetamine use disorder

Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Abstinence, Lapse, or Relapse: ≥2 weeks, N (%) and/or longest consecutive period, mean (SD) | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
Topiramate
Elkashef, 2012^87^ 8 sites (US) N=140 17 wks follow-up | 69 vs 71 Topiramate 200mg/day 13 wks BBCET 1x/wk UA 3x/wk | 63.6% male Age: 38.0 (8.62) Race: 82.9% White, 2.1% AA/Black Education yrs: 12.9 (1.85) Employment: 24.3% unemployed | NR | % of subjects with a UA(-) wk during wks 6–12 (max tx dose): No significant difference, P=0.13 % who reduced use days by ≥25% of baseline: 64.2% vs 42.3%; P=0.03 (wks 6–12) % who reduced use days by ≥50% of baseline rate: 49.1% vs 26.9%; P=0.027 (wks 6–12) | 77 completed study: 39/69 (56.5%) vs 38/71 (53.5%) | WD: 2 (2.9%) vs 2 (2.8%) Severe AEs: 13 | Low
Baclofen vs gabapentin
Heinzerling, 2006^88^ Single-site (US) N=88 16 wks follow-up | 25 vs 26 vs 37 Baclofen 20mg/day vs Gabapentin 800mg/day 16 wks 90-min relapse prevention group sessions 3x/wk UA 3x/wk | 69% male Age: 32 Race: 59% White, .01% AA/Black Education yrs: 12 | Longest abstinence, days: Baclofen 25.39 (29.17); Gabapentin 18.85 (21.67); Placebo 21.00 (24.72); P=ns N (%) with 3 consecutive wks abstinence: Baclofen 11 (44%); Gabapentin 9 (34.6%); Placebo 15 (40.5%); P=ns | % UA(-) samples: Baclofen 50.3% (±37%); Gabapentin 37.1% (±35%); Placebo 37.7% (±37%) P=0.577 | 39 completed study: Baclofen 15 (60%), Gabapentin 9 (35%), Placebo 15 (41%) P=0.157 | WD: 1(4%) vs 0 vs 0 Severe AEs: NR | Low

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AA = African American; AE = adverse event; BBCET = Brief Behavioral Compliance Enhancement Treatment; C = control group; CBT = Cognitive Behavioral Therapy; hr = hour(s); MA = methamphetamine; mg = milligrams; NR = not reported; NS = not significant; OR = odds ratio; P = p-value; ROB = risk of bias; SD = standard deviation; SES = socioeconomic status; sig = statistically significant; T = treatment group; UA = urinalysis; US = United States of America; wk(s) = week(s); WD = withdrawal; yr(s) = year(s).

### Pharmacotherapies that are Prescribed for Other Substance Use Disorders

#### Opioid Antagonists

##### Naltrexone

##### Summary of Findings

We identified 4 RCTs for use of naltrexone in treatment of amphetamine/methamphetamine use disorder.^89–92^ Overall, there was insufficient evidence related to the effect of naltrexone on sustained abstinence and the reduction of amphetamine/methamphetamine use. There was low strength evidence that naltrexone is more effective than placebo improving treatment retention. We found moderate strength of evidence that naltrexone did not cause harms.

##### Detailed Results

All trials analyzed had small sample sizes (80–100 participants) with varying lengths of treatment duration (10–24 weeks). Only 1 unclear-ROB trial (N=100) examined abstinence from amphetamine use of greater than 3 weeks as an outcome.^91^ This study enrolled men who have sex with men (MSM) at a single site in the US and randomized patients to receive intermuscular XR-NTX (380 mg) or placebo injection once monthly for a total of 12 weeks. All participants also completed weekly cognitive behavioral therapy (CBT) and motivational interviewing (MI) counseling, and provided UA samples once weekly. Few achieved abstinence at trial completion (14% vs 20%; P=0.6). There were no differences in rate of positive UA between groups or treatment retention. (See Table 14 for study-level data and Conclusions Table I for a summary of findings).

The 3 remaining studies took place internationally and did not report abstinence.^89,90,92^ Runarsdottir et al randomized Icelandic patients transitioning from inpatient to outpatient setting to receive monthly injection of naltrexone (XR-NTX 380 mg) or placebo for 24 weeks total; both groups received concomitant 4-weeks residential or intensive outpatient (IOP) psychosocial treatment program (consisting of motivational, cognitive behavioral, and relapse prevention counseling) and submitted once-weekly UA for testing. There were no differences in likelihood of having positive UA for methamphetamine between groups (IRR 1.00, 95% CI 0.38–2.68, P=0.99), and retention was similar in both groups. The study reported no serious AEs. There was unclear risk of bias due to unclear blinding procedures and because UA was only assessed weekly. (See Table 14 for study-level data and Conclusions Table I for a summary of findings).

Jayaram-Lindstrom et al, a low-ROB RCT, randomized newly abstinent Swedish patients (ie, completed 2-week lead-in period) to receive naltrexone (50 mg/day) or placebo for 12 weeks total. Both groups also received weekly 60-minute relapse prevention therapy and participants submitted once-weekly UAs. The treatment group had a higher percentage of negative UA than placebo (65.2% vs 47.7%, P<.05). There were no significant differences in retention (RR=1.12 95% CI 0.83–1.50). (See Table 14 for study-level data and Conclusions Table I for a summary of findings).

Tiihonen et al, an unclear-ROB multi-site trial in Russia, randomized 100 patients with cooccurring amphetamine and opioid dependence to receive naltrexone implant (Prodetoxon 1000 mg implant) or placebo for 10 weeks. The treatment group had higher percentage of negative UA than placebo but this difference was not statistically significant (40% vs 24%, P=.09). Treatment participants had increased retention versus placebo (52% vs 28%, P=0.01) (See Table 14 for study-level data and Conclusions Table I for a summary of findings).

##### Treatment Retention

We conducted a meta-analysis on treatment retention for all 4 studies on naltrexone (see Figure 17). The combined effect on treatment retention was similar between naltrexone and placebo (RR 1.11, 95% CI 0.88 to 1.41). Statistical heterogeneity was significant (P=.05). Patients treated with naltrexone were significantly more likely to complete treatment compared with placebo in one 10-week study with low risk of bias.^90^ In an analysis combining 3 studies with treatment of 12 weeks or longer, there was no significant heterogeneity, and no difference in retention between the naltrexone and placebo groups (RR 1.03, [95% CI 0.93 to 1.13] see Figure 18). Due to multiple studies with unclear risk of bias and reporting of inconsistent results, we assessed this as low strength of evidence.

Figure 17 Treatment retention among patients with amphetamine/methamphetamine use disorder in studies that compared naltrexone vs placebo

Figure 18 Treatment retention among patients with amphetamine/methamphetamine use disorder in studies that compared naltrexone vs placebo with at least 12 weeks follow-up

Table 14 Placebo-controlled trials of opioid antagonists for treating amphetamine/methamphetamine use disorder

Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Findings: T vs C | | | | Risk of bias
Setting Total N^*^ Mean follow-up | N, T vs C; Treatment dose & duration; Concomitant treatment; UA frequency | Population^*^ Male % Age, mean (SD) Race % SES % | Abstinence ≥2 consecutive weeks, N (%) | Overall use, UA-confirmed | Retention in treatment | Treatment withdrawals due to AE; Severe AEs | Risk of bias
Naltrexone
Runarsdottir, 2017^89^ Single site, inpatient transitions to outpatient (Iceland) N=100 24 wks follow-up | 51 vs 49 XR-NTX (380 mg/monthly injection) 24 wks 4-week residential or IOP treatment program UA 1x/wk | 75% Male Age: 31.6 (8.6) Race: 100% white Education: 72% general educ or less Employment: 69% unemployed Homeless: 12% | NR | UA (+) IR 1.00, 95% CI 0.38–2.68; P=0.99 | 49 completed study: 24/51 (47%) vs 25/49 (51%); RR=0.92 (0.62–1.38) | Severe AEs: None WD due to severe AE: None | Unclear
Tiihonen, 2012^90^ Multi-site (Russia) N=100 10 wks follow-up | 50 vs 50 Naltrexone (Prodetoxon 1000mg implant) 10 wks No concomitant tx UA 1x/wk | 89% Male Age: 28 (4.1) Race, education, employment: NR | NR | Proportion UA (-): 40% vs 24%; P=0.09 | 40 completed study: 26/50 (52%) vs 14/50 (28%); RR=1.86 (1.11–3.12) | Severe AEs: None WD due to severe AE: None | High
Coffin, 2017^91^ Single site, outpatient (US) N=100 12 wks follow-up | 50 vs 50 XR-NTX (380 mg/month) 12 wks CBT and MI 30min/wk UA 1x/wk | 96% Male Age: 43.2 (8.5) Race: 55% White Education: 26% high school or less Employment: 70% unemployed | Achieved abstinence at completion of trial: 7 (14%) vs 10 (20%); P=0.6^*^ | Risk of UA (+): IRR=0.95; 95% CI=0.76–1.20) | 93 completed study: 47/50 (94%) vs 46/50 (92%); RR=1.86 (1.11–3.12) | Severe AEs: 3 WD due to severe AE: None | Unclear
Jayaram-Lindstrom, 2008^92^ Single-site Inpatient (Sweden) N=80 12 wks follow-up | 40 vs 40 Naltrexone (50mg/day) 12 wks 60 minute relapse prevention therapy/wk UA 1x/wk | 78% Male Age: 39.3 (8.1) Education: 10.7 years (SD 1.6) Race: NR | NR | % UA (-) during trial: 65.2% ±36.1 vs 47.7% ±33.7 Mean number UA (-) significantly higher for tx; P<0.05 | 55 completed study: 29/40 (72.5%) vs 26/40 (65%); RR=1.12 (0.83–1.50) | Severe AEs: None WD due to severe AE: None | Low

* Descriptors may represent the total study population or the subgroup assigned to active treatment unless a significant difference occurred between study arms at baseline.

Other benefits/harms Not Reported in these studies

Abbreviations: AE = adverse event; AA = African American; C = control group; CBT = Cognitive Behavioral Therapy; CI = confidence interval; hr = hour(s); IOP = Intensive outpatient; MA = methamphetamine; mg = milligrams; NR = Not reported; NS = not significant; OR = Odds ratio; P = p-value; ROB = risk of bias; SD = standard deviation; SES = socioeconomic status; sig = statistically significant; T = treatment group; UA = urinalysis; US = United States; wk(s) = week(s); yrs = years.

### Other Pharmacotherapies

Three additional studies examined the effects of other drugs or drug combinations for methamphetamine use disorder. No effects were reported in studies of citicoline,^93^ Ondansetron,^94^ or PROMETA (which contains a combination of flumazenil, gabapentin, and hydroxyzine).^95^ As there was only 1 study on each of these medications, the strength of evidence for each is considered insufficient.

### Pharmacotherapies for Comorbid Amphetamine/Methamphetamine and Opioid Use Disorders

#### Summary of Findings

We identified only 1 study that examined pharmacotherapies for comorbid amphetamine/methamphetamine and opioid use disorder.^90^ This RCT compared naltrexone to placebo and found a nonsignificant trend towards the use of naltrexone for rates of amphetamine-negative UAs. Naltrexone was significantly better than placebo for study retention.

#### Detailed Findings

There was 1 trial that examined the effect of naltrexone on amphetamine use in an opioid dependent population.^90^ This study took place at multiple sites in Russia and randomized 100 patients to receive naltrexone implant (Prodetoxon 100 mg implant) or placebo for 10 weeks. There was no concurrent behavioral health intervention administered. Patients randomized to receive naltrexone had higher rates of negative UA for amphetamines compared to placebo though this was not statistically significant (40% vs 24%, P=0.09). At 10 weeks, the naltrexone arm had improved retention compared to placebo (52% in treatment vs 28% in placebo, P=0.01). As above, there was unclear risk of bias. Strength of evidence was insufficient due to lack of studies (see Conclusions Table J).

## Key Question 4 Are there known subpopulations for whom different forms of pharmacotherapy is most/least effective for amphetamine/methamphetamine use disorder?

### Summary of Findings

We identified 3 RCTs^82,85,87^ and 1 systematic review^81^ that examine subgroup differences in adults with methamphetamine use disorder. Included subgroups are: methamphetamine severity at baseline,^81,82,85^ methamphetamine-negative UA at randomization,^87^ gender,^82^ comorbid or lifetime alcohol use disorder,^87^ comorbid ADHD,^82^ comorbid depression,^82^ and HIV status.^85^

Overall, findings are inconclusive due to methodological issues, as well as the limited number of studies examining each subpopulation. However, it is possible that bupropion,^82^ but not aripiprazole^85^ or psychostimulants,^81^ may be more effective in reducing methamphetamine use in individuals who are less severely addicted at baseline,^82^ and topiramate may be more effective in individuals who produce a negative urine screen at randomization.^87^ In addition, bupropion may be more effective for males with methamphetamine use disorder than for females, and there is a possibility that some individuals with comorbid depression may experience more benefit than placebo.^82^ No differences were found by ADHD diagnosis,^82^ lifetime alcohol use disorder,^87^ or HIV status.^85^

### Findings by Subpopulation

#### Methamphetamine Severity at Baseline

Two RCTs^82,85^ and 1 systematic review^81^ examined the differential effect of baseline severity treatment response and outcomes. A RCT^82^ comparing bupropion to placebo found that for individuals who had reported using methamphetamine 18 days or fewer in the last 30 days, bupropion was more effective than placebo for increased methamphetamine-negative weeks over time, with greater rates of decrease in negative methamphetamine urine samples and more participants achieving at least 1 methamphetamine-negative week. No such effect was found for those who reported more than 18 days of use.^82^ Neither the RCT comparing aripiprazole to placebo,^85^ nor the systematic review examining psychostimulants (including bupropion)^81^ found significant differences in any outcome of interest by baseline severity (see Table 15 for more detail).

#### Methamphetamine-negative at Randomization

One RCT comparing topiramate to placebo examined differences in the effect of pharmacotherapy by baseline UA results.^87^ Findings indicate that participants with negative final UAs prior to randomization had more methamphetamine-negative weeks (in weeks 6–12 [primary outcome]), regardless of treatment group. There was no difference between topiramate and placebo in week 6; however, over the course of weeks 6–12, participants with negative final UAs assigned to topiramate experienced more methamphetamine-negative weeks (P=0.02). There was no significant treatment effect in the full sample (see Table 15 for more detail).

#### Gender

One RCT comparing bupropion to placebo examined differential treatment effects by gender.^82^ Findings indicate that receiving bupropion was more effective than placebo for increased methamphetamine-negative weeks over time for males (P=0.04), but not for females (P=0.71) (see Table 15 for more detail).

#### Comorbid Depression

One RCT comparing bupropion to placebo examined the role of comorbid depression in the treatment of methamphetamine use disorder.^82^ The study found a nonsignificant trend favoring bupropion associated with increased methamphetamine-negative weeks over time for less-depressed participants (P=0.08), but not for participants with higher rates of depression (P=0.58; see Table 15 for more detail).

#### Comorbid Attention Deficit Hyperactivity Disorder

One RCT comparing bupropion to placebo examined differences in treatment effects in patients with and without comorbid ADHD.^82^ There was no difference between bupropion and placebo in methamphetamine-negative weeks over time by ADHD diagnosis (see Table 15 for more detail).

#### Comorbid or Lifetime Alcohol Use Disorder

A single RCT that compared topiramate to placebo explored the impact of a lifetime history of alcohol use disorder on treatment effects.^87^ The study found that a history of alcohol use disorder was not significantly associated with methamphetamine-negative weeks (in weeks 6–12 [primary outcome]) nor were there differences in treatment effect by history of alcohol use disorder (see Table 15 for more detail).

#### HIV Status

One RCT compared differences in the effect of aripiprazole versus placebo in participants with and without HIV.^85^ Findings indicate no difference between aripiprazole and placebo in methamphetamine-negative samples by HIV status (RR 0.85 [95% CI 0.63 to 1.15], P=0.29; see Table 15 for more detail).

Table 15 Subgroup analyses in studies of pharmacotherapy for amphetamine/methamphetamine use disorder, stratified by population characteristic

Study N | N, T vs C; Tx dose and duration; concurrent intervention UA frequency | Abstinence | Use | Retention | Summary
Addiction Severity at Baseline
Elkashef 2008^82^ 5 sites (US) N=151 18 wks follow-up Lower use (<=18/30 days), N=71 Higher use (>18/30 days) N=80 | 79 vs 72 Bupropion SR 300 mg/day 12 wks 90 min/3x weekly CBT-relapse prevention group UA 3x/wk | NR | For participants with lower baseline use at baseline, but not higher (0.68), bupropion was more effective than placebo for increased methamphetamine-negative weeks over time (P=0.03), with a greater rate of decrease in negative methamphetamine samples (P=0.04) and more participants achieving at least one methamphetamine-negative week (56% vs 40%). | NR | Bupropion was more effective than placebo for increased methamphetamine-negative weeks over time for participants with lower but not higher rates of baseline use, with greater rates of decrease in negative methamphetamine samples and more participants achieving at least one methamphetamine-negative week.
Coffin, 2013^85^ 1 site (US) N=90 12 wks follow-up 3–7 days/wk N=71 < 3 days/wk N=19 | 45 vs 45 Aripiprazole 20 mg/day (MTD) 12 wks 30 min/1x weekly individual psychotherapy (combination of CBT, MI) UA 1x/wk | NR | There was no difference between aripiprazole and placebo when comparing light (P=0.7) and heavy users (P=0.3) in methamphetamine-negative samples. | NR | There was no difference between aripiprazole and placebo when comparing light and heavy users in methamphetamine-negative samples.
Bhatt, 2016^81^ 17 RCTs N=1,387 | Systematic review of psychostimulants (includes bupropion) | No differences associated with any frequency of use (3 RCTs, N=353; combined OR 0.92 [95% CI 0.54 to 1.54) or low frequency of use (2 RCTs, N=288; combined OR 1.24 [95% CI 0.65 to 1.45]); no difference by frequency of use P=0.67. | NR | No differences associated with any frequency of use (12 RCTs, N=896; combined OR 1.19 [95% CI 0.85 to 1.66) or low frequency of use (2 RCTs, N=288; combined OR 1.29 [95% CI 0.69 to 2.40]); no differences by frequency of use P=0.83. | There were no significant differences between psychostimulants and placebo in sustained abstinence or retention by frequency of use.
Methamphetamine-negative UA at Randomization
Elkashef, 2012^87^ N=140 | 69 vs 71 Topiramate 200mg/day 13 wks BBCET 1x/wk UA 3x/wk | NA | Ss with negative final UAs prior to randomization had more methamphetamine-negative weeks (in weeks 6–12), regardless of treatment group. No difference between topiramate and placebo in week 6. However, over the course of weeks 6–12, participants with negative final UAs assigned to topiramate experienced more methamphetamine-negative weeks (P=0.02). There was no significant treatment effect in the full sample. | NA | Topiramate was more effective than placebo for methamphetamine-negative weeks over time for only participants with a negative UA just prior to randomization, and not for the entire sample. Similarly, participants with a final negative UA had more methamphetamine-negative weeks regardless of treatment group.
Gender
Elkashef 2008^82^ 5 sites (US) N=151 18 wks follow-up Male N=101 Female N=50 | 79 vs 72 Bupropion SR 300 mg/day 12 wks 90 min/3x weekly CBT-relapse prevention group UA 3x/wk | NR | For males (P=0.04) but not females (P=0.71), receiving bupropion was more effective than placebo for increased methamphetamine-negative weeks over time. | NR | Bupropion was more effective than placebo for increased methamphetamine-negative weeks over time for males but not females.
Comorbid Depression
Elkashef 2008^82^ 5 sites (US) N=151 18 wks follow-up Ham-D <=12 N=121 Ham-D >12 N=30 | 79 vs 72 Bupropion SR 300 mg/day 12 wks 90 min/3x weekly CBT-relapse prevention group UA 3x/wk | NR | There was a nonsignificant trend favoring bupropion associated with increased methamphetamine-negative weeks over time for less depressed participants (P=0.08), but not for participants with higher rates of depression (P=0.58). | NR | There was a nonsignificant trend favoring bupropion associated with increased methamphetamine-negative weeks over time for less depressed participants, but not for participants with higher rates of depression.
Comorbid ADHD
Elkashef 2008^82^ 5 sites (US) N=151 18 wks follow-up No ADHD N=131 ADHD N=20 | 79 vs 72 Bupropion SR 300 mg/day 12 wks 90 min/3x weekly CBT-relapse prevention group UA 3x/wk | NR | There was no difference between bupropion and placebo in methamphetamine-negative weeks over time by ADHD diagnosis. | NR | There was no difference between bupropion and placebo in methamphetamine-negative weeks over time by ADHD diagnosis.
Comorbid or Lifetime Alcohol Use Disorder
Elkashef, 2012^87^ | | NA | A history of alcohol use disorder was not significantly associated with methamphetamine-negative weeks (in weeks 6–12) nor were there differences in treatment effect by the presence of alcohol use disorder. | NA | History of alcohol use disorder was not significantly associated with methamphetamine-negative weeks (in weeks 6–12) nor were there differences in treatment effect by history of alcohol use disorder.
HIV Status
Coffin, 2013^85^ 1 site (US) N=90 12 wks follow-up HIV+ N=28 HIV− N=62 | 45 vs 45 Aripiprazole 20 mg/day (MTD) 12 wks 30 min/1x weekly individual psychotherapy (combination of CBT, MI) UA 1x/wk | NR | There was no difference between aripiprazole and placebo in methamphetamine-negative samples by HIV status (RR 0.85 [95% CI 0.63 to 1.15], P=0.29). | | There was no difference between aripiprazole and placebo in methamphetamine-negative samples by HIV status.

Abbreviations: AA = African American; ADHD = attention deficit hyperactivity disorder; AE = adverse event; BBCET = Brief Behavioral Compliance Enhancement Therapy; CBT = Cognitive Behavioral Therapy; CI = confidence interval; HAM-D = Hamilton Depression Rating Scale; HIV = human immunodeficiency virus; P = p-value; MI = Motivational Interviewing; MTD = Methadone; NR = Not reported; P = p-value; RCT = randomized control trial; RR = Risk ratio; Ss = subjects; UA = urinalysis; US = United States

#### Subgroup Analysis of Contingency Management as a Co-intervention

A multifactorial trial of sertraline for methamphetamine dependence (N=229) compared use versus non-use of CM within both active treatment and placebo groups.^83^ Fifty-three percent of participants randomized to the sertraline group completed the trial, compared with 49% in the placebo group. The difference was not statistically significant (RR 1.06, 95% CI 0.82 to 1.37).