# Introduction

Stimulant use disorders, specifically cocaine and methamphetamine use, present ongoing public health problems in the United States, with major medical, psychiatric, cognitive, socioeconomic, and legal consequences.^3^ Cocaine use disorder is associated with increased risk of stroke, cardiac abnormalities, and risk of HIV infections.^4^ There are more emergency department visits associated with cocaine compared with other illicit substances. In 2013, there were 1.5 million cocaine users aged 12 or older in the United States, and 855,000 of them experienced dependence or abuse during the past year.^5^ Potential short-term harms from cocaine use include disturbance in heart rhythm and heart attacks, neurological effects, including seizures, and gastrointestinal complications. Long-term use can lead to increased irritability, restlessness, panic attacks, paranoia, and psychosis. Other health effects associated with long-term cocaine use include malnourishment, damage to the heart and cardiovascular system, and stroke. Cocaine use can be accompanied by drug craving, tolerance, and development of withdrawal symptoms such as depression or anxiety, fatigue, agitation, difficulty concentrating, and physical symptoms (chills, tremors, sleeplessness, muscle aches, and nerve pain), as well as increased craving for cocaine. In some instances, regular daily users of cocaine may have increased rates of suicidal thoughts.

Methamphetamine addiction is a serious public health problem in the United States. Several US cities consider methamphetamine as the drug of abuse associated with the “most serious consequences.” Adverse effects of methamphetamine include restlessness, insomnia, hyperthermia, and possibly convulsions. Long-term use can lead to addiction, paranoia, mood disturbances, agitation, psychosis, and cognitive impairment.^6^ Following prolonged use, discontinuation of methamphetamine can result in withdrawal symptoms that include dysphoric mood, paranoia, violent behavior, fatigue, sleep disturbances, and increased appetite.^6,7^

Currently there are no accepted FDA-approved pharmacotherapy treatment options available for cocaine or methamphetamine use disorder. Several pharmacotherapies have been proposed as possible experimental interventions to promote reduction in use or cessation. Currently, psychotherapy (including cognitive behavioral therapy, drug counseling, and relapse prevention, among others) is offered as the primary treatment for stimulant addiction. Contingency management is also commonly used in treating stimulant use disorders. We conducted this evidence synthesis to provide an up-to-date examination of the benefits and risks associated with the use of various pharmacotherapy treatments for increasing treatment retention and promoting cessation/reduction of stimulant use.