# Executive Summary

## Introduction

Stimulant use disorders, specifically cocaine and methamphetamine use, present ongoing public health problems in the United States, with major medical, psychiatric, cognitive, socioeconomic, and legal consequences.

Currently there are no accepted FDA-approved pharmacotherapy treatment options available for cocaine or methamphetamine use disorders. Several pharmacotherapies have been proposed as possible experimental interventions to promote reduction in use or cessation. Currently, psychotherapy (including cognitive behavioral therapy, drug counseling, relapse prevention, etc) is offered as the primary treatment for stimulant addiction. In addition, contingency management strategies use incentives to increase engagement in treatment and reduce drug use. In order to guide future research and policy decisions for the Veterans Health Administration (VHA), the Office of Mental Health and the Seattle and Philadelphia Centers for Substance Abuse Treatment & Education (CESATE) asked the Veterans Affairs Evidence-based Synthesis Program (ESP) to provide an up-to-date examination of the benefits and risks of various pharmacologic treatments of stimulant use disorder. Specifically, this review examined 1) the benefits and harms of pharmacotherapy for cocaine use disorder, 2) subpopulations for whom different forms of pharmacotherapy are most/least effective for cocaine use disorder, 3) the benefits and harms of pharmacotherapy for amphetamine/methamphetamine use disorder, and 4) subpopulations for whom different forms of pharmacotherapy are most/least effective for amphetamine/methamphetamine use disorder.

## Methods

### Data Sources and Searches

We developed search strategies in consultation with a research librarian. We searched multiple data sources from database inception through November 2017.

### Study Selection

Using pre-specified inclusion criteria, we evaluated titles and abstracts for relevance; a random sample of abstracts was dual-reviewed to ensure reliability between reviewers. The remaining abstracts were decided by a single reviewer. Two independent reviewers assessed articles for inclusion, and discordant results were resolved through consensus. We included systematic reviews of randomized controlled trials (RCTs) that directly compared pharmacological interventions against each other, placebo, usual care, or psychotherapy in adults with cocaine or amphetamine/methamphetamine use disorders. We also included individual RCTs that were more recently published or were not examined by the included systematic reviews. We excluded studies and comparisons examining patients with comorbid psychotic spectrum or bipolar disorders.

### Data Abstraction and Quality Assessment

One reviewer abstracted data into a customized database and a second reviewer checked entries for accuracy. From each study, we abstracted the following where available: study setting; subpopulations; inclusion and exclusion criteria; demographic information; addiction severity at baseline; details of active and comparator arms including concomitant treatments, number of urinalyses (UAs) per week, dose, and duration; outcome data including abstinence, use, retention, and harms including withdrawals from treatment and severe adverse events.

Two reviewers independently assessed the risk of bias (ROB) of each study as low, high, or unclear (Appendix D) using a tool developed by the Cochrane Collaboration.^1^

### Data Synthesis and Analysis

We qualitatively synthesized the evidence for each key question, and conducted meta-analyses when combinable outcomes were reported among studies of the same drug or drug class. For studies in which an outcome of interest was collected but not completely reported, we contacted the authors to request the data elements needed for meta-analysis. For trials that had comparable interventions and outcome measures, we combined the trials in meta-analysis using RevMan 5.3 software to estimate odds ratios under the assumption of random effects.^2^

## Results

### Summary of Results for Key Questions

#### KQ1 What are the benefits and harms of pharmacotherapy for cocaine use disorder?

We identified 46 RCTs and 7 systematic reviews that examined outcomes of interest of pharmacotherapy for cocaine use disorder.

With some exceptions, we found insufficient to low strength evidence that most of the drug classes examined did not improve abstinence, use, or treatment retention. It is difficult to draw strong conclusions given the limitations of this body of evidence. Many of the studies were small trials with limited power, methodologic deficiencies, and high enough attrition rates to further limit assessment of treatment effectiveness. Across studies there was significant variability in population, setting, co-interventions, number of study visits and UAs per week, and the outcomes reported.

There were several areas for which there may be potential benefit. We found low strength evidence that psychostimulants as a class, the antidepressant bupropion, and topiramate may be effective in increasing continuous abstinence at 2 weeks or more.

There were a few areas for which there was consistent evidence of no effect, or of a negative effect. There is moderate to high strength evidence that antidepressants (specifically, selective serotonin reuptake inhibitors [SSRI]s and tricyclic antidepressants [TCAs]) do not improve abstinence, use, or retention. In addition, there is moderate strength evidence that anticonvulsants do not improve overall use or retention, and low to moderate strength evidence of no benefit of dopamine agonists on abstinence or retention. We found moderate strength of evidence that SSRIs increase risk of study withdrawal due to adverse events, and that disulfiram is associated with lower retention than placebo. We found moderate strength of evidence that patients treated with disulfiram are less likely to complete treatment compared with placebo.

We found mostly insufficient evidence across 3 SRs and 1 trial in individuals with comorbid cocaine and opioid use disorders (OUD). However, we did find moderate strength evidence that disulfiram and antidepressants as a class, particularly desipramine, are associated with lower retention. Similar to findings for the overall population, we found low strength evidence of a potential benefit of psychostimulants and bupropion for the achievement of sustained abstinence.

#### KQ2 Are there known subpopulations for whom different forms of pharmacotherapy are most/least effective for cocaine use disorder?

We identified 15 RCTs and 1 systematic review that examined subgroup differences in adults with cocaine use disorder.

Overall, findings are inconclusive due to the limited number of studies examining each subpopulation and are hampered by methodological issues as noted above. However, it is possible that baclofen and naltrexone may be particularly effective when treating long-term cocaine users. In addition, the ability to achieve sustained abstinence or produce a cocaine-negative urine sample may be a good predictor of treatment success. We also found that buspirone and naltrexone may have a lesser or even a negative effect in women, that adults with comorbid depression who experience a clinically significant mood response to venlafaxine may experience a reduction in cocaine use, and that chronic heroin users may benefit from a combination of methadone and aripiprazole. Findings suggest no differences in effect by self-reported cannabis use and the presence of alcohol use disorder or attention deficit disorder (ADHD). In two studies of different drug classes the effects of pharmacotherapy were similar in patients receiving and not receiving a contingency management co-intervention.

#### KQ3 What are the benefits and harms of pharmacotherapy for amphetamine/methamphetamine use disorders?

We identified 14 RCTs and 1 systematic review that examined outcomes of interest of pharmacotherapy for amphetamine/methamphetamine use disorders.

Similar to the body of research examining pharmacotherapy for cocaine use disorder, studies evaluating pharmacotherapy for amphetamine/methamphetamine use disorders had largely high or unclear ROB and were underpowered. Co-interventions differed widely and rates of retention varied greatly. Some studies examined methamphetamine or amphetamine use disorders exclusively, and others combined the two. For nearly all pharmacotherapies and almost all the outcomes, findings were either null or insufficient to form conclusions. We found low strength evidence that methylphenidate and topiramate may result in a reduction in use.

We identified only 1 RCT (unclear risk of bias) conducted in patients with comorbid amphetamine/methamphetamine and opioid use disorder. The study found that naltrexone improved study retention.

#### KQ4 Are there known subpopulations for whom different forms of pharmacotherapy are most/least effective for amphetamine/methamphetamine use disorder?

We identified 3 RCTs and 1 systematic review that examine subgroup differences in adults with amphetamine/methamphetamine use disorder.

Overall, findings are inconclusive due to methodological issues, as well as the limited number of studies examining each subpopulation. However, it is possible that bupropion, but not aripiprazole or psychostimulants, may be more effective in reducing methamphetamine use in individuals who have less addiction severity at baseline, and that topiramate may be more effective in individuals who produce a negative urine drug screen at randomization. In addition, bupropion may be more effective for males with methamphetamine use disorder than for females, and for individuals with comorbid depression. We did not find differences by ADHD diagnosis, lifetime alcohol use disorder, or human immunodeficiency virus (HIV) status. There was insufficient evidence examining whether or not CM co-interventions modified pharmacotherapeutic effects.

### Abbreviated Summary of Findings Tables

The tables that follow contain an abbreviated summary of findings for each drug or drug class, and are intended to provide a broad overview of the results. More detailed summary tables on the effects of each drug and the strength of the evidence are provided in the full report.

The abbreviated summary tables convey the direction of the effect and strength of the evidence as follows:

[underlined: Direction of effect] | | [underlined: Strength of Evidence]
Unclear (no color) | NA | No evidence or not applicable
No difference | ∅ | Insufficient
Evidence of benefit | ★ | Low
Mixed findings | ★★ | Moderate
Favors placebo | ★★★ | High

The tables are listed in the following order:

- Table i. Mental health pharmacotherapies for cocaine use disorder
- Table ii. Other pharmacotherapies for cocaine use disorder
- Table iii. Mental health pharmacotherapies for comorbid cocaine and opioid use disorders
- Table iv. Other pharmacotherapies for comorbid cocaine and opioid use disorders
- Table v. Pharmacotherapies for amphetamine/methamphetamine use disorder
- Table vi. Pharmacotherapies for comorbid opioid and amphetamine/methamphetamine use disorders

Table i Mental health pharmacotherapies for cocaine use disorder

| Abstinence | Use | Relapse | Lapse | Retention | Harms
All Antidepressants | ★★ | ★★ | ★ | ★ | ★★★ | ★★
All Antipsychotics | ★ | ★ | ∅ | ∅ | ★★ | ∅
All Tricyclic Antidepressants | ★ | ∅ | NA | NA | ★★★ | ★★
Aminoketone: Bupropion | ★ | ★ | NA | NA | ★★ | ∅
Anxiolytics: Busiprone | ∅ | NA | NA | ∅ | ∅ | ∅
Atypical Antidepressant: Mirtazapine | NA | ∅ | NA | NA | NA | ∅
Cognitive Enhancing Drugs: Memantine, Atomoxetine | ∅ | ∅ | ∅ | NA | ∅ | ∅
First Generation Antipsychotics: Haloperidol | NA | NA | NA | NA | ∅ | NA
Other Antipsychotics: Reserpine | ∅ | ∅ | NA | NA | NA | NA
Psychostimulants: Dexamphetamine, Mazindol, Methamphetamine, Methylphenidate, Mixed Amphetamine Salts, Modafinil, Lisdexamphetamine, Selegiline (drugs combined in analysis) | ★ | ★ | NA | NA | ★★ | ★★
Second Generation Antipsychotics: Aripiprazole, Olanzapine, Risperidone, Quetiapine (drugs combined in analysis) | ★ | ∅ | ∅ | ∅ | ★★ | ∅
Selective Serotonin Reuptake Inhibitors (SSRIs): Fluoxetine and Sertraline | NA | NA | ★ | ★ | ★★ | ★
Serotonin and Norepinephrine Reuptake Inhibitor (SNRI): Venlafaxine | ∅ | ∅ | NA | NA | ∅ | ∅

Table ii Other pharmacotherapies for cocaine use disorder

| Abstinence | Use | Retention | Harms
Disulfiram | ★ | ∅ | ★★ | ★
Varenicline | NA | ∅ | ∅ | ∅
Opioid antagonist: Naltrexone | ★ | ∅ | ★ | ∅
Camprosate | NA | ∅ | ∅ | NA
Opioid agonists: Buprenorphine plus naloxone | ∅ | ∅ | ∅ | NA
Opioid agonists: Methadone vs buprenorphine | ∅ | NA | ∅ | NA
Muscle Relaxant: Baclofen | ★ | ★ | ★ | ★
Anticonvulsants: Carbamazepine, gabapentin, lamotrigine, phenytoin, tiagabine, topiramate and vigabatrin (drugs combined in analysis) | NA | ★★ | ★★ | NA
Anticonvulsant: Vigabatrin | ★ | ★ | ★ | ∅
Anticonvulsant: Topiramate | ★ | ∅ | ★★ | ∅
Dopamine agonists: Amantadine, bromocriptine, L dopa/Carbidopa, pergolide, cabergoline hydergine, and pramipexole | ★ | NA | ★★ | NA

Table iii Mental health pharmacotherapies for comorbid cocaine and opioid use disorders

| Abstinence | Use | Relapse | Lapse | Retention | Harms
Aminoketone: Bupropion | ∅ | ∅ | NA | NA | ★ | ∅
Antipsychotics: Aripiprazole, Risperidone | NA | ∅ | ∅ | ∅ | ★ | ∅
Any Antidepressant | ★ | ∅ | NA | NA | ★★ | ★★
Psychostimulants: Dexamphetamine, Mazindol | ∅ | ★ | NA | NA | ★ | NA
Selective Serotonin Reuptake Inhibitor: Fluoxetine | NA | NA | NA | NA | ∅ | ∅
Tricyclic Antidepressants: Desipramine | ∅ | NA | NA | NA | ★★ | ★

Table iv Other pharmacotherapies for comorbid cocaine and opioid use disorders

| Abstinence | Use | Retention | Harms
Disulfiram | ∅ | ∅ | ★★ | NA
Varenicline | ∅ | ∅ | ∅ | ∅
Opioid agonists: Buprenorphine plus naloxone | ∅ | ∅ | ∅ | ∅
Opioid agonists: Methadone vs buprenorphine | ∅ | NA | ∅ | NA

Table v Pharmacotherapies for amphetamine/methamphetamine use disorder

| Abstinence | Use | Retention | Harms
All Antidepressants | ★★ | ∅ | ★★ | ★
Aminoketone: Bupropion | ★ | ★ | ★★ | ∅
Atypical Antidepressant: Mirtazapine | NA | ∅ | ∅ | ∅
SSRI: Sertraline | ∅ | NA | ∅ | NA
Atypical Antipsychotics: Aripiprazole | ∅ | ★ | ∅ | ∅
Psychostimulants: Modafinil, Dexamphetamine, Methylphenidate^*^ | ★ | ∅ | ★ | NA
Baclofen vs gabapentin | ∅ | ∅ | ∅ | ∅
Anticonvulsant: Topiramate | NA | ★ | ★ | ★
Opioid antagonist: Naltrexone | ∅ | ∅ | ★ | ★★

* We found low strength evidence that methylphenidate may result in a reduction in use.

Table vi Pharmacotherapies for comorbid opioid and amphetamine/methamphetamine use disorders

| Abstinence | Use | Retention | Harms
Opioid antagonist: Naltrexone | NA | ∅ | ∅ | ∅

## Discussion

We found no strong, consistent evidence that any drug class was effective in increasing abstinence, reducing use, or improving retention rates for participants with cocaine use disorders. Psychostimulants, bupropion, and topiramate may improve cocaine abstinence. Sertraline may be useful to prevent relapse in detoxed/abstinent patients. Antipsychotics may improve treatment retention. In populations with co-morbid opioid use, psychostimulants and antidepressants may increase cocaine abstinence. We found moderate to high strength evidence that antidepressants, disulfiram, and anticonvulsants (apart from topiramate) are unlikely to be effective in nonabstinent patients. For methamphetamine use disorder, we found less promising results, though methylphenidate and topiramate may be effective at reducing use. There are several promising areas deserving of further research including the use of bupropion, the use of topiramate, treatment of abstinent patients to prevent relapse, and treatment of patients with comorbid opioid use disorder. It is possible that the lack of significant findings was due to insufficient power to detect differences. Future studies need to be larger and need to assess clinically relevant and uniform outcomes, including reduction in use and defined periods of abstinence outcomes. Contingency management and behavioral interventions, along with pharmacotherapy, should continue to be explored.

## Abbreviations Table

Abbreviation | Term
AA | African American
ADHD | Attention deficit hyperactivity disorder
AE | Adverse event
AHRQ | Agency for Healthcare Research and Quality
BBCET | Brief Behavioral Compliance Enhancement Treatment
BUP | Buprenorphine
CBT | Cognitive behavioral therapy
CI | Confidence interval
CM | Contingency management
df | Degrees of freedom
DSM | Diagnostic and Statistical Manual of Mental Disorders
EBM | Evidence-based Medicine
EPC | Evidence-based Practice Center
ESP | Evidence-based Synthesis Program
EtOH | Alcohol dependence
FDA | Food and Drug Administration
HAM-D | Hamilton Depression Rating Scale
HIV | Human immunodeficiency virus
hr | Hour
HR | Hazard ratio
HSR&D | Health Services Research and Development Service
IOP | Intensive outpatient
IQR | Interquartile range
IRR | Incidence rate ratio
ITT | Intention-to-treat
KQ | Key question
LDA | Longest duration of abstinence
MA | Methamphetamine
MA | Meta-analysis
MET | Motivation Enhancement Therapy
mg | Milligram
MI | Motivational interviewing
min | Minutes
MSM | Men who have sex with men
MTD | Maximum tolerated dose
MTD | Methadone
NA | Not applicable
NCT | National Clinical Trial register number (ClinicalTrial.gov)
NIH | National Institutes of Health
NMDA | N-methyl-D-aspartate
NOS | Not otherwise specified
NR | Not reported
NS | Not significant
OR | Odds ratio
OUD | Opioid use disorder
P | P-value
PICOTS | Population, interventions, comparators, outcomes, timing, and setting
PLA | Placebo
QUERI | Quality Enhancement Research Initiative
RCT | Randomized controlled trial
RD | Risk difference
ROB | Risk of bias
RR | Relative risk
SAE | Severe adverse event
SD | Standard deviation
SE | Standard error
SEM | standard error of the mean
SERT | Sertraline
SES | Socioeconomic status
SMD | standard mean difference
SNRI | Serotonin and Norepinephrine Reuptake Inhibitor
SOE | Strength of evidence
SR | Systematic review
Ss | Subjects
SSRI | Selective Serotonin Reuptake Inhibitors
SUD | Substance use disorder
TAU | Treatment as usual
TEP | Technical expert panel
TLFB | Timeline Follow-back Interview
TTM | Transtheoretical Model
tx | Treatment
UA | Urinalysis
US | United States
VHA | Veterans’ Health Administration
WD | Withdrawal
wk | Week
XR-NTX | Injectable Extended-Release Naltrexone
yr | Year