# Appendix D Quality Assessment Criteria

Domain | Criteria^1^
Sequence generation | Was the allocation sequence adequately generated?
Allocation concealment | Was allocation adequately concealed?
Blinding | Was knowledge of the allocated intervention adequately prevented during the study?
Incomplete outcome data | Were incomplete and missing outcome data adequately addressed?
Selective outcome reporting | Are reports of the study free of suggestion of selective outcome reporting?
Other sources of bias | Was the study apparently free of other problems that could put it at a high risk of bias?
Overall assessment of potential for bias | Low/Unclear/High

Quality Assessment of Included Studies

Author, year | Sequence generation | Allocation concealment | Blinding | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Risk of Bias
Afshar, 2012^17^ | NR | NR | Yes | No | Yes | No | High
Baldacara, 2016^18^ | Yes | Unclear | Yes | Yes | Yes | Yes | Low
Bisaga, 2010^19^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Carroll, 2012^21^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Carroll, 2016^20^ | Yes | Yes | Yes | NR | Yes | Yes | Low
Coffin, 2013^85^ | Yes | Yes | Yes | Yes | Yes | No | Unclear
Coffin, 2017^91^ | Yes | Yes | Yes | Yes | Yes | No | Unclear
Colfax, 2011^84^ | Yes. | Yes | Yes | Yes | Yes | No | Unclear
Elkashef, 2008^82^ | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear
Elkashef, 2012^87^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Heinzerling, 2006^88^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Low
Hersh, 1998^23^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Jayaram-Lindstrom, 2008^92^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Kahn, 2009^26^ | Unclear | Yes | Yes | Yes | Yes | Yes | Low
Kampman, 2011^28^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Kosten, 2013^31^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Ling, 2016^34^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Mancino, 2014^36^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Moran, 2017^39^ | Yes | Yes | Yes | Yes | Yes | No | High
Oliveto, 2011^40^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Oliveto, 2012^41^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Pettinati, 2008^43^ | Yes | Yes | Yes | Yes | Yes | No | Unclear
Pettinati, 2014^42^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Plebani, 2012^44^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear
Poling, 2010^45^ | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear
Raby, 2014^46^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Runarsdottir, 2017^89^ | Yes | Unclear | Yes | Yes | Yes | No | Unclear
Schmitz, 2004^51^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Schmitz, 2009^50^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Schottenfeld, 1997^54^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Schottenfeld, 2005^53^ | Yes | Yes | Yes | No | Yes | Yes | Unclear
Schottenfeld, 2014^52^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Shoptaw, 2003^56^ | Unclear | Unclear | Yes | Yes | Unclear | Yes | Unclear
Shoptaw, 2006^83^ | Yes | Yes | Yes | Unclear | Yes | No | Unclear
Tiihonen, 2007^86^ | No | Unclear | No | Yes | Yes | No | High
Tiihonen, 2012^90^ | Yes | Yes | Yes | Yes | Yes | No | High
Walsh, 2013^61^ | Yes | Yes | Yes | Yes | Yes | No | Unclear
Winhusen, 2014^62^ | Yes | NR | Yes | Yes | Yes | No | High