# Appendix C Study Selection

## Inclusion codes, code definitions, and criteria

1. Is the population made up of non-pregnant/non-postpartum adults with cocaine or amphetamine use disorder?
  - Yes → Proceed to 2.
  - No → STOP. Code X1 (Excluded population)
2. Does the intervention include pharmacotherapy to treat stimulant use disorder? Exclude: Pharmacotherapies intended to treat comorbid substance dependence (eg, alcohol or heroin) rather than stimulant use.
  - Yes → Proceed to 3.
  - No → STOP. Code X2 (Not relevant to topic)
3. Is the study design a randomized controlled trial with followup of 4 weeks or longer?
  - Yes → Proceed to 4.
  - No → STOP. Code X3 (Excluded study design or publication type)
  - Exclude: Narrative or non-systematic review; opinion/editorial; cross-sectional study; case report/case series; case-control; cohort study; conference proceeding published before 2015.
    Also exclude RCTs that compare dosage levels of the same drug, without a placebo group or other active comparator.
  Note: Systematic reviews, meta-analyses, and other important background/discussion papers should be coded B-X3, followed by notes/keywords.
  Examples:
  - B-X3 – SR, pearl references
  - B-X3 – narrative review with good background
  - B-X3 – useful for discussion
  - B-X3 – discusses timing and frequency of UA in trials
4. Does the study measure substance use by urinalysis at least once per week?
  - Yes → Proceed to 5.
  - No → STOP. Code X4 (No outcomes of interest)
  [underlined: Note: We will not analyze the following outcomes]:
  - Craving or withdrawal symptoms
  - Mental health outcomes (anxiety/depression)
  - Medication adherence via pill count or biomarkers
  - Lab values other than UA for measuring abstinence
5. Do all study arms receive identical treatment with the exception of the medication being tested? For example, if the active arm receives psychotherapy, the comparator arm should receive an identical form of psychotherapy with the same frequency and level of intensity as the primary arm.
  - Yes → Proceed to 6.
  - No → STOP. Code X5 (Unbalanced study design)
6. Does the comparator arm consist of another active medication for treating stimulant use disorder?
  - Yes → Code H2H. Go to 7.
  - No → Code RCT. Go to 7.
7. Indicate which stimulant disorder is the primary target of the intervention (cocaine, methamphetamine, or either/both).
8. Enter the medication(s) being tested.
9. Enter any applicable subgroups. Examples:
  - Opioid: Methadone/buprenorphine-maintained or comorbid opioid-dependent
  - ADHD: Attention-deficit hyperactive disorder
  - Alcohol: comorbid alcohol abuse
  - Depression/anxiety: identified at study entry
  - PTSD: identified at study entry
  - MSM
  - HIV, HCV