# Appendix B Technical Expert Panel

- Adam Gordon, MD, MPH, FACP
  Professor of Medicine, University of Pittsburgh
  Co-Director, Interdisciplinary Addictions Program for Education and Research, Pittsburgh VAMC
  Core Investigator, CHERP
- Steven Batki, MD
  Professor of Psychiatry, University of California, San Francisco
  Director, Addiction Psychiatry Research Program, San Francisco VAMC
- Bryon Adinoff, MD
  Professor and Distinguished Professor of Alcohol and Drug Abuse Research, University of Texas Southwestern Medical Center (Dallas)
  Director of Research for Mental Health, VA North Texas Health Care System
- Larissa Mooney, MD
  Director, Addiction Medicine Clinic, University of California – Los Angeles
  Physician, Mental Health, VA Greater Los Angeles Health Care System
- Kyle Kampman, MD
  Professor of Psychiatry at the Hospital of the University of Pennsylvania and the Presbyterian
  Medical Center of Philadelphia
  Medical Director, The Charles O’Brien Center for the Treatment of Addictions
- Richard De La Garza, Ph.D.
  Professor of Psychiatry Research, Baylor College of Medicine, Houston, TX, US
  Professor and Director of Research, Department of Psychiatry, Division of Internal Medicine, The University of Texas MD Anderson Cancer Center, Houston, TX
- Peter Hauser, MD
  Mental Health Program Coordinator, VA Long Beach Healthcare System