# Acknowledgments

This topic was developed in response to a nomination by Dr. Dominick DePhilippis in conjunction with Dr. Karen Drexler, Deputy National Mental Health Program Director, Office of Mental Health Services, for an evidence review to examine the effectiveness and best practices for pharmacotherapy for stimulant use disorder. The scope was further developed with input from the topic nominators (ie, Operational Partners), the ESP Coordinating Center, the review team, and the technical expert panel (TEP).

In designing the study questions and methodology at the outset of this report, the ESP consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

The authors gratefully acknowledge the following individuals for their contributions to this project:

## Operational Partners

Operational partners are system-level stakeholders who have requested the report to inform decision-making. They recommend Technical Expert Panel (TEP) participants; assure VA relevance; help develop and approve final project scope and timeframe for completion; provide feedback on draft report; and provide consultation on strategies for dissemination of the report to field and relevant groups.

- Karen Drexler
  Deputy National Mental Health Program Director
  Office of Mental Health Services (10P4M)
- Dominick DePhilippis
  Education Coordinator, Philadelphia CESATE
  Office of Mental Health Services and Philadelphia CESATE

## Technical Expert Panel (TEP)

To ensure robust, scientifically relevant work, the TEP guides topic refinement; provides input on key questions and eligibility criteria, advising on substantive issues or possibly overlooked areas of research; assures VA relevance; and provides feedback on work in progress. TEP members are listed below:

- James McKay, PhD
  University of Pennsylvania
  Philadelphia CESATE
  Philadelphia, PA
- Eric Hawkins, PhD
  University of Washington
  VA Puget Sound Health Care System
  Seattle, WA
- Andrew Saxon, MD
  University of Washington
  Seattle CESATE
  Seattle, WA
- Adam Gordon, MD, MPH, FACP
  University of Pittsburgh
  Pittsburgh VAMC
  CHERP
  Pittsburgh, PA
- Steven Batki, MD
  University of California – San Francisco
  San Francisco VAMC
  San Francisco, CA
- Bryon Adinoff, MD
  University of Texas Southwestern Medical Center (Dallas)
  VA North Texas Health Care System
  Dallas, TX
- Larissa Mooney, MD
  University of California – Los Angeles
  VA Greater Los Angeles Health Care System
  Los Angeles, CA
- Kyle Kampman, MD
  University of Pennsylvania
  The Charles O’Brien Center for the Treatment of Addictions
  Philadelphia, PA
- Richard De La Garza, PhD
  Baylor College of Medicine
  The University of Texas MD Anderson Cancer Center
  Houston, TX
- Peter Hauser, MD
  VA Long Beach Healthcare System
  Long Beach, CA

## Peer Reviewers

The Coordinating Center sought input from external peer reviewers to review the draft report and provide feedback on the objectives, scope, methods used, perception of bias, and omitted evidence. Peer reviewers must disclose any relevant financial or non-financial conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The Coordinating Center and the ESP Center work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.