# SUMMARY AND DISCUSSION

We reviewed 7,944 titles and abstracts from the search of electronic databases, bibliographies, and other sources, and 152 were identified as potentially relevant. Upon full-text review, we excluded 127 studies for a total of 24 included studies from 25 publications. Of the 518 clinical trials identified by our search of trial registry websites, one study met inclusion criteria;^40^ however, this study and all data reported on ClinicalTrials.gov are represented in an included publication.^41^ We identified 21 articles (20 primary studies) for Key Question 1, 4 primary studies for Key Question 2, and no primary studies for Key Question 3.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question 1 In adults with psychotic spectrum disorders

Overall there is insufficient evidence from which to draw conclusions about the effectiveness of interventions to improve medication adherence in patients with psychotic spectrum disorders.

Interventions vary widely, with included studies evaluating multicomponent behavioral interventions, interventions involving family members, interventions involving technology, pharmacist-led interventions, system-level interventions, and others. Overall, findings are mixed. However, there is low strength of evidence that interventions involving family members, and those involving technology, such as e-monitoring or daily reminder messages may result in improved psychopharmacological adherence; this indicates that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect. Table 14 provides additional detail.

Table 14 Psychotic Spectrum Disorders: Summary of Medication Adherence Outcomes

Type of Intervention | Study Design (Combined N) | Findings | Strength of Evidence | Comments
Behavioral Multicomponent -Adherence Therapy | 2 RCTs (N = 370) | Mixed findings: one study (low ROB) reported better adherence compared to usual care on the MAQ and SAI-C at 12 months, and the other (low ROB) reporting no difference from usual care on the CDR, DAI-30, and MARS at 12 weeks post-discharge. | Insufficient | Evidence from only 2 studies, with mixed findings.
Behavioral Multicomponent -Compliance Therapy | 2 RCTs (N = 130) 1 NRCT (N = 70) 1 Prospective Cohort (N = 30) | Mixed findings: better MARS scores with Compliance Therapy at 1 month but not 6 months in 1 study (high ROB); better DAI and compliance scores as compared with routine management plus supportive counseling through 18 month follow in 1 study (high ROB); no benefit to Compliance Therapy up to 6 months in 2 studies (compared to nonspecific counseling and Compliance Therapy; moderate ROB). | Insufficient | Inconsistent findings among 4 studies. Risk of bias due to study design.
Other Behavioral Multicomponent | 1 RCT (N = 88) | No difference between group cognitive behavioral therapy (CBT) plus Motivational Interviewing (MI) and group psychoeducation plus MI (moderate ROB). | Insufficient | Evidence from only one study.
Depot plus Behavioral Multicomponent | 1 Trial (randomization unclear) (N = 57) 1 Prospective Cohort (N = 30) | Findings indicated improved adherence related to the use of depot antipsychotics plus a behavioral multicomponent intervention (compared to usual care or no comparator) as measured by injection visits up to one year, and injection visits, TRQ, Morisky scale, DAI, and AMQ up to 25 weeks (moderate ROB). | Insufficient | Heterogeneity among interventions; risk of bias due to study design.
Family Intervention | 3 RCTs (N = 449) | Better adherence with family interventions as measured by clinician rating/blood plasma and pharmacy records/family-report as compared to usual care in 2 studies (moderate ROB). No difference when controlling for time in a third study examining a culturally modified family intervention as compared to the standard family intervention and monthly sessions (moderate ROB). | Low | Heterogeneity among interventions.
System-level Intervention | 1 NRCT (N = 70) | Nonsignificant trend towards better adherence for the system-level intervention, compared with Compliance Therapy (moderate ROB). | Insufficient | Evidence from only one study.
Pharmacist-led | 1 Prospective Cohort w/post hoc comparison (N = 30) | No significant difference over time or between groups (high ROB). | Insufficient | Evidence from only one study; potential risk of bias due to study design flaws.
Technology Interventions | 4 RCTs (N = 434) | Mixed findings on e-monitoring/MEMS: better adherence in 1 study as compared to pill counts and self-reported adherence (high ROB), conflicting results in 1 study as compared to a pharmacy based intervention and usual care (low ROB). Telephone plus SMS resulted in nonsignificant adherence improvement vs telephone or SMS alone (moderate ROB); SMS alone resulted in significantly better adherence than usual care (moderate ROB). | Low | Mixed findings and heterogeneous interventions.
Motivational Interviewing (MI) | 1 RCT (N = 114) | One study found no benefit to MI over usual care as measured by the MAQ or DAI (low ROB). | Insufficient | Evidence from only one study.
Cognitive Adaptation Training (CAT) | 2 RCTs (N = 240) | One study found that both CAT and Pharm-CAT resulted in better adherence than usual care, with no difference between the 2 (moderate ROB). The second study comparing Pharm-CAT to e-monitoring reported mixed results (low ROB). | Insufficient | Evidence from 2 studies that used different comparators.
Shared Decision Making | 1 RCT (N = 107) | One study found no benefit to a shared decision-making over usual care as measured by the MARS and plasma levels (high ROB). | Insufficient | Evidence from only one single study.

Note. Studies comparing interventions may be accounted for more than once.

Abbreviations: AMQ = Attitude towards Medication Questionnaire; CAT = Cognitive Adaptation Training; CBT = Cognitive Behavioral Therapy; CDR = Concentration to Dose Ratio; DAI = Drug Attitude Inventory; MAQ = Medication Adherence Questionnaire; MARS = Medication Adherence Rating Scale; MEMS = Medication Event Monitoring System; MI = Motivational Interviewing; NRCT = Non-randomized controlled trial; ROB = Risk of bias; SAI-C = Schedule for the Assessment of Insight - C; TRQ = Tablet Routine Questionnaire.

There is limited evidence of the effectiveness of depot antipsychotics in combination with a medication adherence intervention, with studies reporting better adherence associated with a psychosocial intervention in patients prescribed a depot antipsychotic as compared with controls, and improved adherence in a homeless population associated with the prescription of depot and a customized multicomponent behavioral intervention. However, despite evidence suggesting a positive effect, the wide differences in the interventions, small sample sizes, the potential for sampling bias in populations prescribed depot antipsychotics, and lack of methodological rigor preclude drawing firm conclusions.

Only one study measured non-psychopharmacological adherence, and found no benefit associated with telephone and/or SMS support.

There is no clear evidence of the effect of medication adherence interventions on patient outcomes. Findings reported for positive, negative, and overall symptom severity are mixed, and there is little support that these interventions improve quality of life. Findings related to functional impairment are also mixed; however, there is limited evidence that interventions involving family members and those including the use of a depot antipsychotic may result in improved functioning. Similarly, while it is unclear whether medication adherence interventions in general are effective in reducing hospitalizations, the time to first hospital readmission, or time spent in the hospital, 2 studies reported a positive effect of interventions on time to relapse, and limited evidence suggests that in general, interventions involving family members may result in better patient outcomes.

### Key Question 2 In adults with bipolar disorder

The 4 studies meeting inclusion criteria for Key Question 2 provide limited evidence of the effectiveness of interventions for medication adherence in patients with bipolar disorder. Three of the 4 studies found a positive effect on psychopharmacological adherence associated with an adherence intervention, with high rates of attrition in the one study reporting no effect. Despite evidence suggesting a generally positive effect, the strength of the evidence is insufficient and thus precludes drawing conclusions, due to the fact that the interventions were heterogeneous, sample sizes were small, and 2 studies showing a positive effect were conducted in Iran, calling into question applicability (see Table 15).

Table 15 Bipolar Disorder: Summary of Medication Adherence Outcomes

Type of Intervention | Study Design; (Combined N) | Findings | Strength of Evidence | Comments
Psychoeducation (individual/group) | 1 RCT (N = 108) 1 NRCT (N = 45) | Both individual and group psychoeducation resulted in better medication adherence pharmacotherapy alone or pharmacotherapy with standard psychotherapy (moderate ROB). | Insufficient | Evidence from only 2 studies, external validity due to setting.
Psychoeducation plus problem solving | 1 RCT (N = 164) | There was no improvement in medication adherence associated with the intervention as compared to usual care (moderate ROB). | Insufficient | Evidence from only one study. Only 75% of the intervention group and 81% of the control group participated in baseline plus one other assessment, and only 49% of the intervention group participated in most or all of the group sessions, with 37% never participating.
Customized Behavioral Multicomponent (psychoeducation, substance use/modified MET, provider communication, medication management) | 1 Prospective Cohort (N = 43) | Customized adherence enhancement (CAE) was associated with better adherence and attitudes towards medication at 3 and 6 months (moderate ROB). | Insufficient | Evidence from only one study; risk of bias due to study design.

Abbreviations: CAE = Customized adherence enhancement; MET = Motivational Enhancement Therapy; NRCT = Non-randomized controlled trial; RCT = Randomized controlled trial; ROB = Risk of bias.

There is no clear evidence to support conclusions regarding the effect of interventions for improving medication adherence on patient outcomes. Findings related to depression, mania, and functional impairment were mixed, and despite limited evidence supporting improvement, the lack of high quality studies, heterogeneity of the interventions, and setting preclude the ability to draw conclusions.

### Key Question 3 In adults with PTSD

We identified no studies meeting inclusion criteria for Key Question 3.

## LIMITATIONS

Our review has a number of limitations. Despite restricting included studies to randomized and non-randomized controlled trials and observational studies that controlled for important confounding variables and included either a comparison group or examined a trend controlling for time (see Table 3), we rated only 4 of the 25 included studies (all 4 were trials) as high-quality studies with a low risk of bias,^46,48,57,58^ with 4^42,43,55,59^ of the 19 trials and 2^45,53^ of the 6 observational studies determined to have a high risk of bias. In many studies, sample sizes were small, bringing into question statistical power. While it would have been ideal to overcome the issue of power by combining studies quantitatively, heterogeneity between studies precluded us from doing so. Studies included in this review evaluate a wide range of interventions in a variety of settings, with vast differences in intervention characteristics and implementation; specific interventions were rarely examined in more than one study. Furthermore, a wide range of measures were used to assess medication adherence, ranging from objective measures to validated short self-report scales, which often found different results even within the same study. Finally, although we did conduct a search for grey literature, we were unable to conduct a formal assessment of publication bias.

## DISCUSSION

We found 24 studies in 25 publications with the potential to inform policies and practices related to medication adherence in patients with severe mental illness in the VHA. Twenty studies (reported in 21 articles) examined patients with psychotic spectrum disorders, and 4 studies were in patients with bipolar disorder. We identified no studies examining patients with PTSD. The interventions designed to improve medication adherence across Key Questions 1 and 2 differed widely, with very few studies evaluating the same specific interventions. Despite a variety of interventions designed to increase psychopharmacological adherence, study limitations (eg, differences in population and setting, heterogeneity among studies, a wide range of comparators, and the challenge of evaluating complex interventions), as well as concerns regarding applicability to the VHA, preclude us from drawing strong conclusions.

There is limited evidence that the involvement of family members, the use of technology (eg, e-monitoring, SMS, telephone), and that the combination of a depot antipsychotic and another intervention may be effective in improving adherence. However, these findings must be interpreted with caution, given the heterogeneity among interventions, the difficulty in determining the contribution of the depot antipsychotic versus the adherence intervention, the methodological limitations, and the lack of consistent replication of any specific intervention. With the exception of interventions involving technology and system-level interventions, many interventions include behavioral or other techniques (eg, MI) that are flexible and designed to adapt to different settings and patients. While these techniques have been found effective in the treatment of other mental health conditions (eg, anxiety, depression, substance abuse), additional research of standardized interventions designed to improve medication adherence is needed to replicate findings across settings and populations in order to better understand their effect on adherence and patient outcomes. Similarly, many of the included studies compare interventions for medication adherence to usual care, rather than an active comparator. Given the population and the nature of mental illness, it is possible that the lack of active controls may result in more frequent provider interaction for the intervention group than for those receiving usual care. More frequent contact alone has the potential to result in improved outcomes, and it is impossible to ascertain whether any effect was due to the intervention or to increased attention. Finally, sampling bias may exist related to baseline differences in the adherence of individuals selected to enroll in studies examining interventions designed to improve medication adherence and those who do not – particularly in studies examining long acting injectable depot antipsychotics.

An additional challenge in accurately assessing the body of research examining medication adherence is the wide range of methods used to assess adherence. We limited our inclusion to studies that assessed adherence using an objective measure such as blood plasma concentration levels, pill counts, e-monitoring/MEMS caps, or using a validated adherence scale.^1^ For studies using multiple adherence measures, it was not uncommon for the determination of adherence to be incongruent, leading to questions related to the validity of commonly used and validated objective and subjective measures.

There is a paucity of research examining the effect of medication adherence interventions on non-psychopharmacological interventions. Given the risk of comorbid health conditions (eg, diabetes, hypertension) in persons with serious mental illness, future research should evaluate the impact of adherence interventions aimed at prevalent comorbid non-psychiatric conditions.

Furthermore, we identified no studies evaluating the potential harms that may result from these interventions. Despite the fact that the potential for harm appears to be low as compared to the risks associated with both the use of and non-adherence to prescribed medication, research documenting relative risk is warranted. Similarly, very few studies evaluated differential effects in subpopulations. It is important to understand whether both the benefits and potential harms differ by subgroup or clinical subpopulation and whether one type of intervention may be more effective than others for a given population or setting.

We identified no studies examining interventions to improve medication adherence in patients with PTSD. Although trauma processing therapies are often the first line of treatment for patients with PTSD, pharmacological interventions are commonly used as adjunctive therapy to alleviate associated symptoms and to treat comorbid conditions. There is limited evidence to suggest that adherence to medication is poor in Veterans with PTSD who are taking medication. Therefore, future research is warranted to determine whether improvements in adherence in this population can be achieved through the use of interventions, or by adapting interventions developed for other patient populations.

### Recommendations for Future Research

Interventions to improve medication adherence in patients with psychotic spectrum disorders and bipolar disorder warrant further investigation, particularly in the form of well-designed RCTs with active comparators of adequate sample size and duration. Furthermore, few studies examine the same intervention, and replication is needed in order to draw conclusions about the effectiveness of a specific program. Several small studies suggest the effectiveness of some of the interventions (eg, interventions including family members). However, many of the interventions are multicomponent and complex, differ widely in their components and implementation, and thus research evaluating standardized interventions is needed.

Research evaluating the effectiveness of interventions to improve medication adherence in patients with PTSD is lacking and needed. For all populations examined in this report, future research is needed to evaluate the effect of these interventions on non-psychopharmacological interventions. In addition, future studies should examine potential adverse events associated with medication adherence interventions. Objective measures should be used to measure medication adherence, and the identification and validation of a gold-standard assessment tool for medication adherence is warranted. Finally, more research is necessary to determine the cost effectiveness and feasibility of interventions for medication adherence in the VHA.

## CONCLUSION

Findings from the studies examining interventions to improve medication adherence in patients with psychotic spectrum disorders are mixed and evaluate a wide range of heterogeneous interventions. Sample sizes were generally small, studies often lacked an active comparison group, and there was wide variation in how adherence was measured among studies. There is limited evidence to support improved adherence associated with interventions involving family members, those involving technology, and those combining a depot antipsychotics with another intervention. Findings were mixed regarding the effectiveness of multicomponent behavioral interventions, with no support for Adherence or Compliance Therapies. In addition, no clear evidence exists to support conclusions regarding the effect of medication adherence interventions on patient outcomes. Very few studies examined interventions for medication adherence in patients with bipolar disorder, and while in general there appears to be a positive effect of these interventions on adherence in this population, interventions were heterogeneous and more research is needed. No studies were found examining PTSD populations. For all populations, methodologically rigorous replication studies of standardized treatments using objective or validated subjective measures of adherence are needed to confirm preliminary results, as is research examining the costs and potential harms associated with the wide array of interventions designed to improve medication adherence.