# RESULTS

Our search of electronic databases, bibliographies, and other sources resulted in a total of 7,944 studies. After title and abstract review, 152 were selected for full-text review. Upon review of the full-text articles, we excluded 127 citations for a total of 24 included studies from 25 publications. Additionally, a search of the ClinicalTrials.gov online trial registry identified 518 clinical trials, and one study met inclusion criteria;^40^ however, this study and all data reported on ClinicalTrials.gov are represented in an included publication.^41^ We identified 21 articles (20 individual primary studies) for Key Question 1, 4 primary studies for Key Question 2, and no primary studies for Key Question 3.

## LITERATURE FLOW

Figure 2 shows the citation yield from electronic database searches and other sources, numbers for exclusions at the abstract and full-text phases, and the final yield of included studies delineated by key question.

Figure 2 Literature Flow Chart

* 7,895 were identified through database searches (Appendix B), and an additional 49 were identified from the bibliographies of relevant systematic reviews and primary studies.

## KEY QUESTION 1 ADULTS WITH PSYCHOTIC SPECTRUM DISORDER

We identified 21 articles meeting inclusion criteria for patients along the psychotic spectrum, with 20 independent studies reporting medication adherence outcomes, and one article^42^ reporting a cost analysis of another included study.^43^ Seven studies examined multicomponent behavioral interventions;^43-49^ 3 studies examined interventions involving family members;^50-52^ one study examined a system-level intervention;^49^ one study examined a pharmacist-led intervention;^53^ 4 studies examined technology interventions (Medication Event Monitoring System [MEMS], telephone, short message service [SMS]);^54-57^ and 4 studies examined other interventions such as MI (1 study),^58^ shared decision-making (1 study),^59^ and environmental supports (2 studies).^57,60^ Two studies examined the combination of depot antipsychotics and an intervention designed to increase medication adherence,^61,62^ one study reported the intervention effect on non-psychopharmacologic medications,^54^ and 2 studies reported outcomes related to costs.^42,57^ Study details are found in Tables 4-11.

Table 4 Psychotic Spectrum Disorders: Multicomponent Behavioral Interventions Medication Adherence Outcomes

Study; N per Group | Sample and Setting | Intervention Groups | Intervention Intensity | Measure; Baseline | First Follow-up | Additional Follow-ups
Adherence Therapy
Gray et al, 2006^46^ G1: 204 G2: 205 | Adults with clinically unstable schizophrenia requiring antipsychotic medication for ≥ 1 year post-baseline. Outpatient settings in the Netherlands, Germany, England, and Italy | G1: Usual care plus Adherence Therapy (AT), a brief cognitive behavioral approach focused on joint decision making including: assessments, medication problem solving, a medication timeline, exploring ambivalence, discussing beliefs and concerns about medication, medication in the future G2: Usual care plus didactic health education | Eight individual 30- to 50-minute weekly sessions | MAQ M(SD) G1 (N = 172): 2.98 (1.24) G2 (N = 194): 2.97 (1.20) | 12 Months: M(SD) G1 (N = 172): 3.20 (1.07) G2 (N = 194): 3.33 (1.02) Difference between groups (all available cases): -0.13 (CI, -0.35 to 0.08), P = .23 Difference between groups (complete cases): -0.15 (CI, -0.34 to 0.05), P = .15
Gray et al, 2006^46^ G1: 204 G2: 205 | Adults with clinically unstable schizophrenia requiring antipsychotic medication for ≥ 1 year post-baseline. Outpatient settings in the Netherlands, Germany, England, and Italy | | Eight individual 30- to 50-minute weekly sessions | SAI-C M(SD) G1 (N = 173): 5.04 (1.39) G2 (N = 189): 4.73 (1.63) | 12 Months: M(SD) G1 (N = 173): 5.22 (1.57) G2 (N = 189): 5.03 (1.55) Difference between groups (all available cases): 0.19 (CI, -0.12 to 0.52), P = .24 Difference between groups (complete cases): -0.16 (CI, -0.32 to 0.29), P = .92
Schulz et al, 2013^48^ G1: 93 G2: 105 | Adults diagnosed with a schizophrenic disorder (without comorbid disorders) recently discharged and prescribed antipsychotic medication with a recommendation of treatment for a least one year following discharge. Hospitals in Germany (3) and Switzerland | G1: Usual care plus Adherence Therapy (AT), a brief cognitive behavioral approach focused on joint decision making including: assessments, medication problem solving, a medication timeline, exploring ambivalence, discussing beliefs and concerns about medication, medication in the future G2: Usual care followed national guidelines for the treatment of schizophrenia and generally included medication, psychotherapy, occupational therapy, and psychoeducation. | Eight individual sessions, 5 as an inpatient, additional 3 after discharge. | CDR (blood serum) M(SD) G1 (N = 54): 3.83(6.80) G2 (N = 39): 4.19(5.79) | 12 Weeks Post Discharge M(SD) G1 (N = 54): 3.34(5.36 G2 (N = 39): 6.36(10.56) F = 2.29, P = NS
Schulz et al, 2013^48^ G1: 93 G2: 105 | | | Eight individual sessions, 5 as an inpatient, additional 3 after discharge. | DAI-30 M(SD) G1 (N = 69): 22.46(6.83) G2 (N = 46): 22.70(6.69) | 12 Weeks Post Discharge M(SD) G1 (N = 69): 22.70(6.59) G2 (N = 69): 22.83(5.89) Difference = -.13, F = .039, P = NS
Schulz et al, 2013^48^ G1: 93 G2: 105 | | | Eight individual sessions, 5 as an inpatient, additional 3 after discharge. | MARS M(SD) G1 (N = 69): 7.55(2.07) G2 (N = 46): 7.46(1.73) | 12 Weeks Post Discharge M(SD) G1 (N = 69): 7.74(2.01) G2 (N = 46): 7.65(1.87) Difference = 0. F not reported.
Compliance Therapy ^ 64 ^
Byerly et al, 2005^45^ G1: 30 | Adults diagnosed with schizophrenia or schizoaffective disorder taking only one oral antipsychotic, and who had been admitted to a psychiatric ward or emergency department for psychiatric purposes within 2 years. Community mental health | G1: Compliance Therapy is a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. | Four to 6 individual face-to-face 30- to 60-minute sessions over the period of a month. | MEMS NR | 1 Month G1: 4% decline (P = .12) | 6 Month G1: Adherence increased by .19 each month from Months 1-6 (P = .83)
Byerly et al, 2005^45^ G1: 30 | | | Four to 6 individual face-to-face 30- to 60-minute sessions over the period of a month. | MEMS NR | Diagnosis of schizoaffective disorder was associated with a larger decrease in adherence between months -1 and +1 (HLM, P = .03) | Greater insight at baseline was associated with a greater increase in adherence in months 2-6 (HLM, P<.01)
Byerly et al, 2005^45^ G1: 30 | | | Four to 6 individual face-to-face 30- to 60-minute sessions over the period of a month. | MARS NR | 1 Month G1: 8.9% increase (P = .04) | 6 Months G1: 1.4% decline per month in months 2-6 (P = .07)
Byerly et al, 2005^45^ G1: 30 | | | Four to 6 individual face-to-face 30- to 60-minute sessions over the period of a month. | DAI NR | 3 Month G1: 15.2% increase (P = .15) | 6 Months G1: .5% decrease (P = .81)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | G1: Routine management plus Compliance Therapy, a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. G2: Routine management plus supportive counseling (no medication issues addressed) | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | DAI M(SD) G1 (N = 39): 45.3(6.8) G2 (N = 35): 44.1(7.7) | At Discharge M(SD) G1 (N = 39): 52.0(5.9) G2 (N = 35): 45.7(8.5) | 1 Month M(SD) G1 (f35): 50.1(6.3) G2 (N = 28): 44.4(8.1)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | DAI M(SD) G1 (N = 39): 45.3(6.8) G2 (N = 35): 44.1(7.7) | At Discharge M(SD) G1 (N = 39): 52.0(5.9) G2 (N = 35): 45.7(8.5) | 6 Months M(SD) G1 (N = 18): 50.4(7.4) G2 (N = 14): 41.9(5.9)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | DAI M(SD) G1 (N = 39): 45.3(6.8) G2 (N = 35): 44.1(7.7) | At Discharge M(SD) G1 (N = 39): 52.0(5.9) G2 (N = 35): 45.7(8.5) | 12 Months M(SD) G1 (N = 28): 49.5(6.9) G2 (N = 16): 44.6(7.5)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | DAI M(SD) G1 (N = 39): 45.3(6.8) G2 (N = 35): 44.1(7.7) | At Discharge M(SD) G1 (N = 39): 52.0(5.9) G2 (N = 35): 45.7(8.5) | 18 Months M(SD) G1 (N = 16): 50.9(6.2) G2 (N = 13): 48.2(8.5)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | DAI M(SD) G1 (N = 39): 45.3(6.8) G2 (N = 35): 44.1(7.7) | Advantage of Compliance Therapy (95% CI 2.5-7.2). Compliance Therapy group had more favorable scores immediately post-treatment and this advantage was retained over all post-intervention assessments, with a mean difference of 15.6%.
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | Compliance (Kemp) rated by multiple sources including primary nurse M(SD) G1 (N = 39): 3.7(1.2) G2 (N = 35): 4.1(1.2) | At Discharge: M(SD) G1 (N = 39): 5.5(0.8) G2 (N = 35): 4.3(1.4) | 3 Months: M(SD) G1 (N = 38): 5.7(1.3) G2 (N = 34): 3.8(2.1)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | Compliance (Kemp) rated by multiple sources including primary nurse M(SD) G1 (N = 39): 3.7(1.2) G2 (N = 35): 4.1(1.2) | At Discharge: M(SD) G1 (N = 39): 5.5(0.8) G2 (N = 35): 4.3(1.4) | 6 Months: M(SD) G1 (N = 36): 5.7(1.8) G2 (N = 33): 3.5(1.9)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | Compliance (Kemp) rated by multiple sources including primary nurse M(SD) G1 (N = 39): 3.7(1.2) G2 (N = 35): 4.1(1.2) | At Discharge: M(SD) G1 (N = 39): 5.5(0.8) G2 (N = 35): 4.3(1.4) | 12 Months: M(SD) G1 (N = 35): 5.5(1.8) G2 (N = 31): 3.6(2.1)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | Compliance (Kemp) rated by multiple sources including primary nurse M(SD) G1 (N = 39): 3.7(1.2) G2 (N = 35): 4.1(1.2) | At Discharge: M(SD) G1 (N = 39): 5.5(0.8) G2 (N = 35): 4.3(1.4) | 18 Months: M(SD) G1 (N = 25): 5.6(1.7) G2 (N = 23): 4.2(2.3)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | There was a significant advantage for the Compliance Therapy group at discharge, and this was maintained throughout post-treatment.
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | AMQ M(SD) G1 (N = 39): 14.8(3.9) G2 (N = 35): 14.0(6.4) | At Discharge: M(SD) G1 (N = 39): 19.4(3.7) G2 (N = 35): 14.9(6.1) P = Significant (NR) | NR
O'Donnell et al, 2003^47^ G1: 28 G2: 28 | Adults 65 and under with a diagnosis of schizophrenia and an IQ>80 recently admitted to the hospital. Hospital in Ireland | G1: Compliance Therapy, a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. G2: Nonspecific counseling | Five individual face-to-face sessions lasting 30-60 minutes. | DAI M(SD) G1 (N = 28): 50(8) G2 (N = 28): 50(7) | 1 Year: M(SD) G1: 51.3(8.2) G2: 53.4(6.2) Difference = -2.1(95% CI, -6.3 to 2.1), P = .32
O'Donnell et al, 2003^47^ G1: 28 G2: 28 | Adults 65 and under with a diagnosis of schizophrenia and an IQ>80 recently admitted to the hospital. Hospital in Ireland | | Five individual face-to-face sessions lasting 30-60 minutes. | 4-point self-report scale and adjusted by key informants G1 (N = 23): 8/23 (35%) G2 (N = 21): 4/21 (19%) | 1 Year: G1: 12/28 G2: 15/28 OR = .65 (95% CI .197 to 2.123)
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | G1: System-Oriented Intervention included providing a brochure and questionnaire on antipsychotic treatment as a basis for conversation between participant/provider, a screening form for identification of compliance problems as the basis for participant/nurse conversation, a reminder box that contained medicine cards, dosage boxes, electronic alarm systems, medication reconciliation, adherence to clinical guidelines G2: Compliance Therapy, a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | Compliance based on self-report, DAI, appointment keeping, PANSS G-12 NR | 6 Months: Difference in compliance score from baseline to follow-up, LOCF: G1: (N = 40): 0.400, 95% CI (-.174 to 0.974), P<0.05 G2: (N = 30): 1.103, 95% CI (.434 to 1.733), P>0.05 Difference between intervention groups, coefficient: Regression, MI: 0.476 (SE 0.362, CI -0.247 to 1.120), P = 0.193
Other Multicomponent Behavioral Intervention
Bechdolf et al, 2005^44^ G1: 40 G2: 48 | Adult inpatients 18-64 years who met criteria for a schizophrenic or related disorder Hospital in Germany | G1: Group CBT included MI, coping strategies, problem solving, relapse prevention, and focused on the treatment of auditory hallucinations and delusions, associated symptoms, relapse prevention, and med adherence. G2: Group psychoeducation focused on improvements in medication compliance and rehospitalization rates and included MI | G1: 16 group sessions over 8 weeks lasting 60-90 minutes. G2: 8 sessions in 8 weeks lasting 60-90 minutes | Compliance (similar to Kemp) w/corroboration with key informants M(SD) G1 (N = 40): 3.9(.3) G2 (N = 48): 3.77(.5) | Post-treatment: M(SD) G1 (N = 37): 3.9(.3) G2 (N = 43): 3.7(.6) | 24 Months: M(SD) G1 (N = 16): 3.4(.7) G2 (N = 25): 2.9(1.1) F = 1.31, P = .26

Note. Studies were conducted in the US unless otherwise specified. Brief descriptions of medication adherence assessments are reported in Appendix E.

Abbreviations: AMQ = Attitude towards Medication Questionnaire; CBT = Cognitive behavioral therapy; CDR = Concentration to Dose Ratio; CI = Confidence Interval; DAI = Drug Attitude Inventory; M = Mean; MAQ = Medication Adherence Questionnaire; MARS = Medication Adherence Rating Scale; MEMS = Medication Event Monitoring System; PANSS = Positive and Negative Syndrome Scale; SAI-C = Schedule for the Assessment of Insight – C; SD = Standard deviation.

Table 5 Psychotic Spectrum Disorders: Family Intervention Medication Adherence Outcomes

Study; N per Group | Sample and Setting | Intervention Groups | Intervention Intensity | Measure; Baseline | First Follow-up | Additional Follow-ups
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | Adults 18-50 of Mexican origin and fluent Spanish speaker with a diagnosis of schizophrenia or schizoaffective disorder who had been without antipsychotic medication for at least one week in the past month without authorization, and lived with their family of origin with a relative willing to participate in family treatment. Community mental health | G1: Usual care plus Multifamily group – Adapted, a culturally modified version of multifamily group therapy, a behavioral family treatment combining psychoeducation and skills training. G2: Multifamily group – Standard plus usual care G3: Usual care | G1: Three individual family joining sessions, a 6 hour multifamily workshop, and twenty-one 90-minute multifamily group sessions twice a month. G2: Same as G1 G3: Monthly 20-minute sessions or more if participant was unstable. | Clinician assessed, self-report, family report, pharmacy data NR | 4 Months: Estimated from graph % Compliant G1: 30% G2: 27% G3: 25% More participants G1 were fully adherent than those in G3 (P<0.01). | 8 Months: Estimated from graph % Compliant G1: 46% G2: 27% G3: 22% G1 was significantly better than G2 (P = .03),
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | | | | Clinician assessed, self-report, family report, pharmacy data NR | 4 Months: Estimated from graph % Compliant G1: 30% G2: 27% G3: 25% More participants G1 were fully adherent than those in G3 (P<0.01). | 12 Months: Estimated from graph % Compliant G1: 52% G2: 32% G3: 25% G1 was significantly better than G2 (P = .04).
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | | | | Clinician assessed, self-report, family report, pharmacy data NR | 4 Months: Estimated from graph % Compliant G1: 30% G2: 27% G3: 25% More participants G1 were fully adherent than those in G3 (P<0.01). | 18 Months: Estimated from graph % Compliant G1: 43% G2: 20% G3: 16% G1 was significantly better than G2 (P = .01).
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | | | | Clinician assessed, self-report, family report, pharmacy data NR | 4 Months: Estimated from graph % Compliant G1: 30% G2: 27% G3: 25% More participants G1 were fully adherent than those in G3 (P<0.01). | 24 Months: Estimated from graph % Compliant G1: 33% G2: 23% G2: 11% P = NS
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | | | | Across the 24 months of the study (12 months of treatment and 12 months of follow-up), there were significant main effects of treatment on adherence for group (F[2,172] = 6.41, P = .003) and for time (F[4,172] = 3.5, P = .009), but not the group X time interaction (F[8,171] = 1.4, P = .22)., and There was no significant difference at any point between the G2 and G3.
Pitschel-Walz et al, 2006^51^ G1: 102 G2: 92 | Adults 18-65 with a diagnosis of schizophrenia or schizoaffective disorder Inpatient wards in Germany | G1: Patients psychoeducation group focused on symptoms, etiology, acute treatment, relapse prevention, psychosocial treatment, and coping strategies. Family psychoeducation group focused on the same as patients, and how they could best support patient. G2: Usual care | G1: Patient groups were eight 60-minute sessions, with 1-4 weekly, then 5-8 monthly. Relative groups were 8 bi-weekly 90-minute sessions. | Clinician assessed, plasma verified NR | Discharge % Very Good/Good Compliance G1: 85, 69/81 G2: 81, 64/79 P = NS | 12 Months: % Very Good/Good Compliance G1: 80, 65/81 G2: 58, 46/79 P<.01
Pitschel-Walz et al, 2006^51^ G1: 102 G2: 92 | Adults 18-65 with a diagnosis of schizophrenia or schizoaffective disorder Inpatient wards in Germany | | G1: Patient groups were eight 60-minute sessions, with 1-4 weekly, then 5-8 monthly. Relative groups were 8 bi-weekly 90-minute sessions. | Clinician assessed, plasma verified NR | Discharge % Very Good/Good Compliance G1: 85, 69/81 G2: 81, 64/79 P = NS | 24 Months: % Very Good/Good Compliance G1: 80, 53/73 G2: 55, 34/64 P<.01
Valencia et al, 2010^52^ G1: 41 G2: 36 | Adult outpatients with a diagnosis of schizophrenia who were adherent to their medication and clinically stable Community mental health in Mexico | G1: Group/family psychosocial skills including medication, decision making, relapse prevention, avoiding drug and alcohol, friendships, improving family relations + usual care G2: Usual care | G1: Patients – 90-minute group session weekly – 40 total sessions in 12 months. Family + patient – 5 sessions G2: 20 minute monthly appointments | Pharmacy data, family report NR | End of Treatment: Adherence = 90% adherent G1: 91.5% G2: 77.8% P<.05

Note. Studies were conducted in the US unless otherwise specified. Brief descriptions of medication adherence assessments are reported in Appendix E.

Abbreviations: NR = Not reported; NS = Not significant.

Table 6 Psychotic Spectrum Disorders: System and Pharmacist Medication Adherence Outcomes

Study; N per Group | Sample and Setting | Intervention Groups | Intervention Intensity | Measure; Baseline | First Follow-up | Additional Follow-ups
System-level Interventions
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | G1: System-Oriented Intervention included providing a brochure and questionnaire on antipsychotic treatment as a basis for conversation between participant/provider, a screening form for identification of compliance problems as the basis for participant/nurse conversation, a reminder box that contained medicine cards, dosage boxes, electronic alarm systems, medication reconciliation, adherence to clinical guidelines G2: Compliance Therapy, a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. | G1: NA G2: Six individual face-to-face sessions and 3 booster session 30-45 minutes in length. | Compliance Scale – self-report, DAI, PANSS G12 NR | 6 Months: Difference in compliance score from baseline to follow-up, LOCF: G1: (N = 40): 0.400, 95% CI (-.174 to 0.974), P<0.05 G2: (N = 30): 1.103, 95% CI (.434 to 1.733), P>0.05 Difference between intervention groups, coefficient: Regression, MI: 0.476 (SE 0.362, CI -0.247 to 1.120), P = 0.193
Pharmacy Interventions
Kavanagh et al, 2003^53^ G1: 15 G2: 15 | Adults diagnosed with psychotic disorders who were inpatients in a psychiatric ward. Hospital in London | G1: Pharmacist-led group including Q & A about medication, rationale, risks of stopping, side effects, risk/benefit evaluations. One session focused on antipsychotics, the second session focused on mood stabilizers + usual care. G2: Usual care | G1: Two one-hour group sessions on consecutive weeks. | Compliance (Kemp), nurse assessed M(SD) G1 (N = 15): 4.60(1.30) G2 (N = 15): 4.47(1.19) | Post Session and 2 Weeks Follow-up: There were no significant differences between groups, over time, nor an interaction.
Technology Interventions (e-Monitoring, SMS, Phone)
Beebe et al, 2014^54^ G1: 10 G2: 10 G3: 10 | Adults 21-68 with a diagnosis of schizophrenia or schizoaffective disorder receiving outpatient care. Community mental health | G1: TIPS + Text. TIPS is a manualized intervention providing weekly telephone support addressing taking medication, attending appointments, coping with symptoms, abstaining from alcohol and other drugs, and getting along with others. G2: TIPS only G3: Text only – text format of the TIPS protocol. Texts were delivered daily | G1: Weekly phone calls and daily texts for 3 months G2: Weekly phone calls for 3 months G3: Daily text messages for 3 months | Home pill counts or % of injections M(SD) NR | 1 Month: M(SD) Month 1: G1 (N = 10): 84.2(22.4) G2 (N = 10): 72(33.7) G3 (N = 10): 72(20.1) | 2 Months: M(SD) G1 (N = 10): 87.5(13.0) G2 (N = 10): 70.1(33.2) G3 (N = 8): 83.9(18.0)
Beebe et al, 2014^54^ G1: 10 G2: 10 G3: 10 | Adults 21-68 with a diagnosis of schizophrenia or schizoaffective disorder receiving outpatient care. Community mental health | | G1: Weekly phone calls and daily texts for 3 months G2: Weekly phone calls for 3 months G3: Daily text messages for 3 months | Home pill counts or % of injections M(SD) NR | 1 Month: M(SD) Month 1: G1 (N = 10): 84.2(22.4) G2 (N = 10): 72(33.7) G3 (N = 10): 72(20.1) | 3 Months: M(SD) G1 (N = 10): 81.1(25.5) G2 (N = 10): 71.5(26.6) G3 (N = 8): 80.9(16.3)
Beebe et al, 2014^54^ G1: 10 G2: 10 G3: 10 | Adults 21-68 with a diagnosis of schizophrenia or schizoaffective disorder receiving outpatient care. Community mental health | | G1: Weekly phone calls and daily texts for 3 months G2: Weekly phone calls for 3 months G3: Daily text messages for 3 months | There was no significant Group × Time interaction for psychiatric medication adherence, F(4,26) = 1.24, P = .31). Nevertheless, findings were in the predicted direction: Mean psychiatric adherence scores for G1 were higher than both G2 (by an average of 5.3%) and G3 (by an average of 13%) at months 1, 2, 3. A post hoc analysis revealed that the power to examine psychiatric medication adherence was 34%.
Frangou et al, 2005^55^ G1: 36 G2: 36 G3: 36 | Adult outpatients 18-64 with a diagnosis of schizophrenia who had at least 2 admissions in preceding 12 months, and prescribed oral medication. Community mental health in London | G1: e-monitoring (MEMS) – medication dispenser that recorded access and transmitted data via the @HOME platform. Staff was alerted if participant took less than prescribed amount. G2: Pill counting by pharmacists at study visits G3: Self-report of adherence using Morisky scale. | G1: e-Monitoring G2: Pharmacist G3: Self-report | See Groups NR | 8 weeks M%(SD) G1 (N = 36): 92.3(4.8) G2 (N = 36): 78.5(14) G3 (N = 36): 75.3(27.6) P = .0001, G1 significantly better than G2 (P = .001) and G3 (P = .007)
Montes et al, 2012^56^ G1: 100 G2: 154 | Adult outpatients 18-65 with a diagnosis of schizophrenia who were clinically stable, prescribed a single antipsychotic, and one affirmative answer on the MAQ Community mental health in Spain | G1: Daily SMS reminders to take their medication, “Please remember to take your medication.” + usual care G2: Usual care | G1: Daily SMS for 3 months | MAQ M(95% CI) G1 (N = 100): 2.2(2.02 to 2.38) G2 (N = 154): 2.2(2.06 to 2.34) | 3 Months: Mean changes M(95% CI) G1: -1.0(-1.02 to -.98) G2: -.7(-.72 to -.68) P = .02 | 6 Months: Mean changes M(95% CI) G1: -1.1(-1.12 to -1.08) G2: -.8(-.81 to -.78) P = .04
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | G1: Pharm-CAT consists of manualized individualized strategies and environmental supports targeting medication adherence G2: Med-eMonitor (MM) is a smart pill container capable of cueing and warning patients, recording side effect complaints, alerting staff of failure to take medication as prescribed. G3: Usual care | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | MEMS NA | Aggregated 3 Month: Mixed-effects regression model yielded a significant treatment group for group (F[2m 365] = 47.29, P<.0001). Time and group X time effects were nonsignificant. G1 and G2 were significantly better than G3 at all time points through treatment and follow-up (P's<.0001). There was no significant difference between G1 and G2.
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | Pill Counts NA | Aggregated 3 Month: The mixed-effects regression model yielded a significant main effect of group (F[2, 116] = 7.83, P<.0001). Time and group X time effects were nonsignificant. G1 had higher adherence by pill count (91%) than either G2 (86%, t[116] = 2.05, P = .04) or G3 (80%, t[115] = 3.95, P = .0001).
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | DAI M(95% CI) G1 (N = 100): 3.4(2.49 to 4.31) G2 (N = 154): 3.1(2.43 to 3.77) | 3 Months: Mean changes M(95% CI) G1: 2.0(1.94 to 2.06) G2: .4(.35 to .45) P = .0003 | 6 Months: Mean changes M(95% CI) G1: 2.3(2.24 to 2.36) G2: .9(.85 to .95) P = .002

Note. Studies were conducted in the US unless otherwise specified. Brief descriptions of medication adherence assessments are reported in Appendix E.

Abbreviations: CAT = Cognitive Adaptation Training; CI = Confidence Interval; DAI = Drug Attitude Inventory; M = Mean; MAQ = Medication Adherence Questionnaire; MEMS = Medication Event Monitoring System; MM = Med-eMonitor; PANSS = Positive and Negative Syndrome Scale; SD = Standard deviation; TIPS = Telephone Intervention Problem Solving for Schizophrenia.

Table 7 Psychotic Spectrum Disorders: Other Medication Adherence Outcomes

Study; N per Group | Sample and Setting | Intervention Groups | Intervention Intensity | Measure; Baseline | First Follow-up | Additional Follow-ups
Motivational Interviewing(MI)
Barkhof et al, 2013^58^ G1: 55 G2: 59 | Adults with schizophrenia or schizoaffective disorder with a psychotic relapse or deterioration following non-adherence to antipsychotics, who have resumed antipsychotics with some clinical improvement. Three sites - Inpatient and outpatients in Amsterdam | G1: A manualized MI intervention based on negative symptoms, positive symptoms, cognitive deficits. G2: Health education on general health topics. | Eight individual 20- to 45-minute sessions over 26 weeks. | MAQ M(SD) G1 (N = 30): 3.00(1.34) G2 (N = 32): 3.13(1.24) | 26 Weeks: M(SD) G1 (N = 30): 3.34(0.99) G2 (N = 32): 3.13(1.12) P = .34 | 6 Months: M(SD) G1 (N = 30): 2.97(1.42) G2 (N = 32): 3.38(1.11) P = .21
Barkhof et al, 2013^58^ G1: 55 G2: 59 | | G1: A manualized MI intervention based on negative symptoms, positive symptoms, cognitive deficits. G2: Health education on general health topics. | Eight individual 20- to 45-minute sessions over 26 weeks. | MAQ M(SD) G1 (N = 30): 3.00(1.34) G2 (N = 32): 3.13(1.24) | There was a significant interaction between MAQ and route of medication administration, suggesting higher adherence rates when using depot medication and received MI, F(1, 59) = 4.53, P = .037, η^2^ = .14.
Barkhof et al, 2013^58^ G1: 55 G2: 59 | | G1: A manualized MI intervention based on negative symptoms, positive symptoms, cognitive deficits. G2: Health education on general health topics. | Eight individual 20- to 45-minute sessions over 26 weeks. | DAI M(SD) G1(N = 30): 6.86(2.18) G2 (N = 32): 6.03(2.30) | 26 Weeks: M(SD) G1(N = 30): 6.86(2.50) G2 (N = 32): 6.38(1.98) P = .72 | 6 Months: M(SD) G1(N = 30): 6.89(2.39) G2 (N = 32): 6.67(2.52) P = .70
Barkhof et al, 2013^58^ G1: 55 G2: 59 | | G1: A manualized MI intervention based on negative symptoms, positive symptoms, cognitive deficits. G2: Health education on general health topics. | Eight individual 20- to 45-minute sessions over 26 weeks. | DAI M(SD) G1(N = 30): 6.86(2.18) G2 (N = 32): 6.03(2.30) | There was a trend level interaction between DAI and age group: F(1,49) = 3.93, P = 05, η^2^ = 0.07, suggesting that participants ≤35 years showed more favorable attitudes toward medication at 6 months follow-up when they received MI vs HE.
Shared Decision-making
Hamann et al, 2007^59^ G1: 39 G2: 47 | Adult inpatients 18-65 with a diagnosis of schizophrenia or schizophreniform disorder Hospital in Germany | G1: Shared decision aid booklet covering pros/cons of medication, psychoeducation, treatment agreement with clinician + usual care G2: Usual care | G1: Decision aid session with nurse and extra planning talk with psychiatrist | MARS and blood plasma NR | 6 Months: #(%) Good Compliance G1 (N = 39): 16(41) G2 (N = 47): 26(55) P = NS | 18 Months: #(%) Good Compliance G1 (N = 30): 18(60) G2 (N = 38): 22(58) P = NS
Cognitive Adaptation Therapy (CAT)
Velligan et al, 2008^60^ G1: 37 G2: 32 G3: 29 | Adult outpatients 18-60 diagnosed with schizophrenia and prescribed an oral antipsychotic Community mental health | G1: CAT consists of manualized individualized strategies and environmental supports designed to include medication adherence, grooming, and activities of daily living G2: Pharm-CAT consisted of only the medication adherence components of CAT G3: Usual care | G1: Individual face-to-face weekly visits lasting 30-45 minutes for 9 months G2: Same as G1, but sessions were generally shorter | Unannounced Home Pill Counts NA | 3 Months: G1 vs G3: P = .04 G2 vs G3: P = .05 15 Months: G2 vs G3: P = .002 All other time points: G1 vs G3: P = .001 G2 vs G3: P = .0001 G1 vs G2 at all time points: P = NS All effect sizes >1 for G1 and G2 at 6 months and after.
Velligan et al, 2008^60^ G1: 37 G2: 32 G3: 29 | Adult outpatients 18-60 diagnosed with schizophrenia and prescribed an oral antipsychotic Community mental health | | G1: Individual face-to-face weekly visits lasting 30-45 minutes for 9 months G2: Same as G1, but sessions were generally shorter | Pharmacy Refill Rates NA | 15 Months: Mixed effects regression main effect for group: F(2, 105) = 3.93, P<.02 No significant effect for time or group X time. G1 significantly more adherent than G3.
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | G1: Pharm-CAT consists of manualized individualized strategies and environmental supports targeting medication adherence G2: Med-eMonitor (MM) is a smart pill container capable of cueing and warning patients, recording side effect complaints, alerting staff of failure to take medication as prescribed. G3: Usual care | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | MEMS NA | Aggregated 3 Months: Mixed-effects regression model yielded a significant treatment group for group (F[2m 365] = 47.29, P<.0001). Time and group X time effects were nonsignificant. G1 and G2 were significantly better than G3 at all time points through treatment and follow-up (P's<.0001). There was no significant difference between G1 and G2.
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | Unannounced Home Pill Counts NA | Aggregated 3 Months: The mixed-effects regression model yielded a significant main effect of group (F[2, 116] = 7.83, P<.0001). Time and group X time effects were nonsignificant. G1 had higher adherence by pill count: (91%) than either G2 (86%, t[116] = 2.05, P = .04) or G3 (80%, t[115] = 3.95, P = .0001).

Note. Studies were conducted in the US unless otherwise specified. Brief descriptions of medication adherence assessments are reported in Appendix E.

Abbreviations: CAT = Cognitive Adaptation Training; CI = Confidence Interval; DAI = Drug Attitude Inventory; M = Mean; MAQ = Medication Adherence Questionnaire; MARS = Medication Adherence Rating Scale; MEMS = Medication Event Monitoring System; MM = Med-eMonitor; SD = Standard deviation.

Table 8 Outcomes Associated with Long-Acting Injectable Adherence

Study; N per Group | Sample and Setting | Intervention Groups | Intervention Intensity | Measure; Baseline | First Follow-up | Additional Follow-ups
Lee et al, 2010^61^ G1: 24 G2: 33 | Participants were outpatients between 17-60 years old, diagnosed with schizophrenia or schizoaffective disorder, and prescribed treatment with a long-acting injectable antipsychotic (depot). Community mental health in Korea | G1: Psychosocial Intervention for Relapse Prevention for depot; included psychoeducation, early warning sign detection, family education with biweekly intervention + usual care. G2: Usual care | G1: 60-minute sessions monthly for 12 months | Biweekly injection visits NA | 12 Months: M%(SD) G1 (N = 21): 94.6(12.2) G2 (N = 25): 75.9(22.2) t(45) = 3.5, P<.01 | 24 Months: M%(SD) G1 (N = 21): 92.1(16.5) G2 (N = 25): 74.2(26.6) t(45) = 2.7, P<.01
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | G1: Depot + CAE is a manualized individual behavioral intervention that consists of 4 modules (psychoeducation, substance use/modified MET, provider communication, medication management). CAE is customized based on an assessment at baseline, with one to 4 modules assigned. | Eight monthly, in-person, 30- to 40-minute sessions | TRQ Screening: M(SD) Past Week: G1: 57.2(33.2) Past Month: G1: 46.1(31.2) | Week 13: M(SD), Change from Baseline (95% CI) Past Week: G1 (N = 10): 12.4(17.3), -42.9 (-60.6 to - 25.2) Past Month: G1 (N = 10): 8.2(11.6), -36.3(-52.9 to - 19.8) | Week 25: M(SD), Change from Baseline (95% CI) Past Week: G1 (N = 10): 13.9(31.4), -38.9(-75.7 to - 2.0) Past Month: G1 (N = 10): 10.1(16.7), -29.6(-54.3 to - 4.8)
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | TRQ Screening: M(SD) Past Week: G1: 57.2(33.2) Past Month: G1: 46.1(31.2) | Past Week: P = .047 Past Month: P = .028
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | Morisky Scale M(SD) G1 (N = 30): 2.5(1.2) | Week 13: M(SD) G1 (N = 30): 1.4(1.3) | Week 25: M(SD) G1 (N = 30):1.4(1.6)
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | Morisky Scale M(SD) G1 (N = 30): 2.5(1.2) | P = .001
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | Injection Frequency NA | Week 13: M(SD) G1 (N = 29): 83(35) | Week 25: M(SD) G1 (N = 29): 76(35)

Note. Studies were conducted in the US unless otherwise specified. Brief descriptions of medication adherence assessments are reported in Appendix E.

Abbreviations: CAE = Customized adherence enhancement; M = Mean; MET = Motivational Enhancement Therapy; NA = Not applicable; SD = Standard deviation; TRQ = Tablet Routine Questionnaire.

Table 9 Psychotic Spectrum Disorders: Non-Psychopharmacological Medication Adherence Outcomes

Study; N per Group | Sample and Setting | Intervention Groups | Intervention Intensity | Measure; Baseline | First Follow-up | Additional Follow-ups
Beebe et al, 2014^54^ G1: 10 G2: 10 G3: 10 | Adults 21-68 with a diagnosis of schizophrenia or schizoaffective disorder receiving outpatient care. Community mental health | G1: TIPS + Text. TIPS is a manualized intervention providing weekly telephone support addressing taking medication, attending appointments, coping with symptoms, abstaining from alcohol and other drugs, and getting along with others. G2: TIPS only G3: Text only – text format of the TIPS protocol. Texts were delivered daily | G1: Weekly phone calls and daily texts for 3 months G2: Weekly phone calls for 3 months G3: Daily text messages for 3 months | Home pill counts or percentage of injections received vs prescribed for depot NR | 1 Month: M(SD) G1 (N = 7): 82.1(19.9) G2 (N = 7): 73.1(21.8) G3 (N = 6): 82.2(26.5) | 2 Months: M(SD) G1 (N = 8): 86.6(7.6) G2 (N = 6): 58.5(27.2) G3 (N = 5): 69.4(33.9)
Beebe et al, 2014^54^ G1: 10 G2: 10 G3: 10 | Adults 21-68 with a diagnosis of schizophrenia or schizoaffective disorder receiving outpatient care. Community mental health | | G1: Weekly phone calls and daily texts for 3 months G2: Weekly phone calls for 3 months G3: Daily text messages for 3 months | Home pill counts or percentage of injections received vs prescribed for depot NR | 1 Month: M(SD) G1 (N = 7): 82.1(19.9) G2 (N = 7): 73.1(21.8) G3 (N = 6): 82.2(26.5) | 3 Months: M(SD) G1 (N = 8): 76.9(20.9) G2 (N = 6): 69.3(24.9) G3 (N = 5): 70.2(27.2)
Beebe et al, 2014^54^ G1: 10 G2: 10 G3: 10 | Adults 21-68 with a diagnosis of schizophrenia or schizoaffective disorder receiving outpatient care. Community mental health | | G1: Weekly phone calls and daily texts for 3 months G2: Weekly phone calls for 3 months G3: Daily text messages for 3 months | Mean non-psychiatric medication adherence scores for G1 were higher (by an average of 11.9%) than G3 at 2 of the 3 follow-ups, and higher than G2 (by an average of 14.9%) months 1, 2, 3. Post hoc analysis revealed that the power to examine non-psychiatric medication adherence was 25%.

Note. Studies were conducted in the US unless otherwise specified. Brief descriptions of medication adherence assessments are reported in Appendix E.

Abbreviations: M = Mean; NR = Not reported; SD = Standard deviation; SMS = Short message service; TIPS = Telephone Intervention Problem Solving for Schizophrenia.

Table 10 Psychotic Spectrum Disorders: Patient Outcomes

Study; N per Group | Sample and Setting | Intervention Groups | Intervention Intensity | Measure; Baseline | First Follow-up | Additional Follow-ups
Adherence Therapy
Gray et al, 2006^46^ G1: 204 G2: 205 | Adults with clinically unstable schizophrenia requiring antipsychotic medication for ≥ 1 year post-baseline. | G1: Usual care plus Adherence Therapy (AT), a brief cognitive behavioral approach focused on joint decision making including: assessments, medication problem solving, a medication timeline, exploring ambivalence, discussing beliefs and concerns about medication, medication in the future G2: Usual care plus didactic health education | Eight individual 30- to 50-minute weekly sessions | BPRS–E M(SD) G1 (N = 175): 45.96 (13.23) G2 (N = 196): 44.31 (12.79) | 12 Months: M(SD) G1 (N = 175): 38.11 (11.33) G2 (N = 196): 37.34 (9.79)
Gray et al, 2006^46^ G1: 204 G2: 205 | Adults with clinically unstable schizophrenia requiring antipsychotic medication for ≥ 1 year post-baseline. | | Eight individual 30- to 50-minute weekly sessions | BPRS–E M(SD) G1 (N = 175): 45.96 (13.23) G2 (N = 196): 44.31 (12.79) | Difference between groups (all available cases): 0.77 (CI, -1.39 to 2.93), P = .48 Difference between groups (complete cases): 0.13 (CI, -1.84 to 2.09), P = .90
Gray et al, 2006^46^ G1: 204 G2: 205 | Adults with clinically unstable schizophrenia requiring antipsychotic medication for ≥ 1 year post-baseline. | | Eight individual 30- to 50-minute weekly sessions | SF-36 M(SD) G1 (N = 175): 38.34 (10.89) G2 (N = 192): 40.12 (12.25) | 12 Months: M(SD) G1 (N = 175): 40.24 (11.97) G2 (N = 192): 41.32 (11.49)
Gray et al, 2006^46^ G1: 204 G2: 205 | Adults with clinically unstable schizophrenia requiring antipsychotic medication for ≥ 1 year post-baseline. | | Eight individual 30- to 50-minute weekly sessions | SF-36 M(SD) G1 (N = 175): 38.34 (10.89) G2 (N = 192): 40.12 (12.25) | Difference between groups (all available cases): -1.08 (CI, -3.49 to 1.33), P = .38 Difference between groups (complete cases): -0.40 (CI, -2.56 to 1.76), P = .72 Sensitivity analysis confirmed the findings.
Schulz et al, 2013^48^ G1: 93 G2: 105 | Adults diagnosed with a schizophrenic disorder (without comorbid disorders), who were recently discharged and prescribed antipsychotic medication with a recommendation of treatment for a least one year following discharge. Hospitals in Germany (3) and Switzerland | G1: Usual care plus Adherence Therapy (AT), a brief cognitive behavioral approach focused on joint decision-making including: assessments, medication problem solving, a medication timeline, exploring ambivalence, discussing beliefs and concerns about medication, medication in the future G2: Usual care followed national guidelines for the treatment of schizophrenia and generally included medication, psychotherapy, occupational therapy, and psychoeducation. | Eight individual sessions, 5 as an inpatient, additional 3 after discharge. | PANSS M(SD) G1 (N = 63): 48.32(13.83) G2: (N = 42): 49.33(14.74) | 12 Weeks Post Discharge M(SD) G1 (N = 63): 44.13(10.67) G2 (N = 42): 50.29(13.67) Difference = -6.16, F = 6.19, P<.05
Schulz et al, 2013^48^ G1: 93 G2: 105 | | | Eight individual sessions, 5 as an inpatient, additional 3 after discharge. | GAF M(SD) G1 (N = 67): 67.05(12.17) G2 (N = 46): 64.2(13.49) | 12 Weeks Post Discharge M(SD) G1 (N = 67): 72.51(11.52) G2 (N = 46): 67.15(13.81) Difference = 5.4, F = .039, P = NS
Compliance Therapy ^ 64 ^
Byerly et al, 2005^45^ G1: 30 | Adults diagnosed with schizophrenia or schizoaffective disorder taking only one oral antipsychotic, and who had been admitted to a psychiatric ward or emergency department for psychiatric purposes within 2 years. Community mental health | G1: Compliance Therapy is a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. | Four to 6 individual face-to-face 30- to 60-minute sessions over the period of a month. | PANSS M(SD) G1: 71.6(17.8) Range 38-105 | 3 Months G1: .8% increase (P = .59) | 6 Months G1: .4% decrease (P = .33)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | G1: Routine management plus Compliance Therapy, a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. G2: Routine management plus supportive counseling (no medication issues addressed) | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | BPRS M(SD) Full: G1 (N = 39): 59.6(14.9) G2 (N = 35): 55.7(13.6) 7-item: G1 (N = 39): 20.3(7.6) G2 (N = 35): 19.2(6.6) | At Discharge M(SD) Full: G1 (N = 39): 37.6(10.1) G2 (N = 35): 37.4(8.5) P = Significant (NR) 7-item: G1 (N = 39): 12.6(5.8) G2 (N = 35): 11.7(3.3) | 6 Months M(SD) 7-item: G1 (N = 36): 14.5(7.2) G2 (N = 31): 16.7(6.9)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | BPRS M(SD) Full: G1 (N = 39): 59.6(14.9) G2 (N = 35): 55.7(13.6) 7-item: G1 (N = 39): 20.3(7.6) G2 (N = 35): 19.2(6.6) | At Discharge M(SD) Full: G1 (N = 39): 37.6(10.1) G2 (N = 35): 37.4(8.5) P = Significant (NR) 7-item: G1 (N = 39): 12.6(5.8) G2 (N = 35): 11.7(3.3) | 12 Months M(SD) 7-item: G1 (N = 35): 13.8(6.3) G2 (N = 28): 15.3(6.2)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | BPRS M(SD) Full: G1 (N = 39): 59.6(14.9) G2 (N = 35): 55.7(13.6) 7-item: G1 (N = 39): 20.3(7.6) G2 (N = 35): 19.2(6.6) | At Discharge M(SD) Full: G1 (N = 39): 37.6(10.1) G2 (N = 35): 37.4(8.5) P = Significant (NR) 7-item: G1 (N = 39): 12.6(5.8) G2 (N = 35): 11.7(3.3) | 18 Months M(SD) 7-item: G1 (N = 25): 12.5(5.6) G2 (N = 20): 14.8(4.1)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | BPRS M(SD) Full: G1 (N = 39): 59.6(14.9) G2 (N = 35): 55.7(13.6) 7-item: G1 (N = 39): 20.3(7.6) G2 (N = 35): 19.2(6.6) | There was a significant effect on the 7-item measure, but no significant effect when accounting for time.
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | GAF M(SD) G1 (N = 39): 36.8(9.5) G2 (N = 35): 37.7(8.9) | At Discharge M(SD) G1 (N = 39): 49.7(13.2) G2 (N = 35): 47.9 11.2) | 3 Months: M(SD) G1 (N = 37): 54.0(17.3) G2 (N = 33): 44.5(10.4)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | GAF M(SD) G1 (N = 39): 36.8(9.5) G2 (N = 35): 37.7(8.9) | At Discharge M(SD) G1 (N = 39): 49.7(13.2) G2 (N = 35): 47.9 11.2) | 6 Months: M(SD) G1 (N = 36): 55.9(17.5) G2 (N = 31): 43.3(10.6)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | GAF M(SD) G1 (N = 39): 36.8(9.5) G2 (N = 35): 37.7(8.9) | At Discharge M(SD) G1 (N = 39): 49.7(13.2) G2 (N = 35): 47.9 11.2) | 12 Months: M(SD) G1 (N = 35): 57.9(16.6) G2 (N = 30): 44.4(14.8)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | GAF M(SD) G1 (N = 39): 36.8(9.5) G2 (N = 35): 37.7(8.9) | At Discharge M(SD) G1 (N = 39): 49.7(13.2) G2 (N = 35): 47.9 11.2) | 18 Months: M(SD) G1 (N = 25): 62.8(18.4) G2 (N = 23) 48.3(14.5)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | GAF M(SD) G1 (N = 39): 36.8(9.5) G2 (N = 35): 37.7(8.9) | There was a significant treatment effect and a significant time × treatment effect with the intervention group showing greater improvement.
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | SAI-E M(SD) G1 (N = 39): 39.7(19.7) G2 (N = 35): 35.4(28.5) | At Discharge: M(SD) G1 (N = 39): 63.0(23.6) G2 (N = 35) 40.6(31.2) | 6 Months: M(SD) G1 (N = 34): 62.6(23.5) G2 (N = 29): 41.9(30.8)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | SAI-E M(SD) G1 (N = 39): 39.7(19.7) G2 (N = 35): 35.4(28.5) | At Discharge: M(SD) G1 (N = 39): 63.0(23.6) G2 (N = 35) 40.6(31.2) | 12 Months: M(SD) G1 (N = 30): 63.4(25.5) G2 (N = 20): 42.6(36.5)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | SAI-E M(SD) G1 (N = 39): 39.7(19.7) G2 (N = 35): 35.4(28.5) | At Discharge: M(SD) G1 (N = 39): 63.0(23.6) G2 (N = 35) 40.6(31.2) | 18 Months: M(SD) G1 (N = 16): 70.7(24.4) G2 (N = 15): 55.3(42.5)
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | SAI-E M(SD) G1 (N = 39): 39.7(19.7) G2 (N = 35): 35.4(28.5) | Patients who received Compliance Therapy had significant greater insight and retained this over the follow-up period with a mean difference of 18.8% on the insight scale.
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | Time to Readmission NA | NA | 18 Months: G1 30% G2 52% Hazard Ratio = 2.2 (95% CI 1.16 to 4.18) for G2 relative to G1
Kemp et al, 1998^43^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | Time Spent in the Hospital NA | M(SD) G1 41.7(75.5) G2 61.6(90.8) Mann-Whitney U test P = .208 | NA
O'Donnell et al, 2003^47^ G1: 28 G2: 28 | Adults 65 and under with a diagnosis of schizophrenia and an IQ >80 recently admitted to the hospital. | G1: Compliance Therapy, a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. G2: Nonspecific counseling | Five individual face-to-face sessions lasting 30-60 minutes. | PANSS M(SD) G1 (N = 28): 71(22) G2 (N = 28): 66(17) | 1 Year: M(SD) G1: 58.2(17) G2: 2.1(21) Difference = 6.1 (95% CI, − 4.7 to 16.9), P = .26 | NA
O'Donnell et al, 2003^47^ G1: 28 G2: 28 | Adults 65 and under with a diagnosis of schizophrenia and an IQ >80 recently admitted to the hospital. | | Five individual face-to-face sessions lasting 30-60 minutes. | SAI M(SD) G1 (N = 28): 9(4) G2 (N = 28): 9(4) | 1 Year: M(SD) G1: 9.9(4.1) G2: 10.4(2.8) Difference = -.5 (95% CI, − 2.4 to 1.5), P = .65 | NA
O'Donnell et al, 2003^47^ G1: 28 G2: 28 | Adults 65 and under with a diagnosis of schizophrenia and an IQ >80 recently admitted to the hospital. | | Five individual face-to-face sessions lasting 30-60 minutes. | GAF M(SD) G1 (N = 28): 36(14) G2 (N = 28): 31(12) | 1 Year: M(SD) G1: 52.7(17.8) G2: 56.9(25.3) Difference = -4.2 (95% CI, 16.8 to 8.4), P = .50 | NA
O'Donnell et al, 2003^47^ G1: 28 G2: 28 | Adults 65 and under with a diagnosis of schizophrenia and an IQ >80 recently admitted to the hospital. | | Five individual face-to-face sessions lasting 30-60 minutes. | QLF M(SD) G1 (N = 28): 67(22) G2 (N = 28): 66(22) | 1 Year: M(SD) G1: 71.8(21) G2: 75.2(25) Difference = -3.4 (95% CI, − 16.6 to 9.9), P = .61 | NA
O'Donnell et al, 2003^47^ G1: 28 G2: 28 | Adults 65 and under with a diagnosis of schizophrenia and an IQ >80 recently admitted to the hospital. | | Five individual face-to-face sessions lasting 30-60 minutes. | Occupancy of hospital beds NA | 1 Year: M(SD) G1: 26(45) G2: 33(57) Difference = -7 (95% CI, −35 to 21), P = .61 | 2 Years: M(SD) G1: 43(60) G2: 50(70) Difference = -7 (95% CI, −42 to 28), P = .69
O'Donnell et al, 2003^47^ G1: 28 G2: 28 | Adults 65 and under with a diagnosis of schizophrenia and an IQ >80 recently admitted to the hospital. | | Five individual face-to-face sessions lasting 30-60 minutes. | Time to first rehospitalization NA | M G1: 440 days (95% CI, 346 to 534) G2: 482 days (95% CI, 378 to 586) P = NS
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | G1: System-Oriented Intervention included providing a brochure and questionnaire on antipsychotic treatment as a basis for conversation between participant/provider, a screening form for identification of compliance problems as the basis for participant/nurse conversation, a reminder box that contained medicine cards, dosage boxes, electronic alarm systems, medication reconciliation, adherence to clinical guidelines G2: Compliance Therapy, a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | PANSS NR | 6 Months: LOCF: G1 (N = 30): 22 G2 (N = 40): 26 P = .036 (adjusted for baseline score, P = .001) Estimate of difference by regression: 4.93, 95% CI (−7.835 to −2.015) MI: −4.478 (CI −9.259 to 0.403), P = .072 (adjusted for baseline score)
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | GAF Median (10; 90^th^ percentile) G1 (N = 30): 33(25, 45) G2 (N = 40): 33(25, 40) | 6 Months: P = NS (MI and LOCF)
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | SWN NR | 6 Months: P = NS (MI and LOCF)
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | Time to first readmission NA | Kaplan-Meier survival proportion estimated from graph: 100 days follow-up: G1 (N = 30): 0.9 G2 (N = 40): 0.7 200 days follow-up: G1 (N = 30): 0.7 G2 (N = 40): 0.5 300 days follow-up: G1 (N = 30): 0.6 G2 (N = 40): 0.4 365 days follow-up: G1 (N = 30): 0.55 G2 (N = 40): 0.35 P = .049
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | Occupancy of hospital beds NA | 12 Months: P = NS
System-level Interventions
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | G1: System-Oriented Intervention included providing a brochure and questionnaire on antipsychotic treatment as a basis for conversation between participant/provider, a screening form for identification of compliance problems as the basis for participant/nurse conversation, a reminder box that contained medicine cards, dosage boxes, electronic alarm systems, medication reconciliation, adherence to clinical guidelines G2: Compliance Therapy, a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | PANSS NR | 6 Months: LOCF: G1 (N = 30): 22 G2 (N = 40): 26 P = .036 (adjusted for baseline score, P = .001) Estimate of difference by regression: 4.93, 95% CI (−7.835 to −2.015) MI: −4.478 (CI −9.259 to 0.403), P = .072 (adjusted for baseline score)
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | GAF Median (10; 90^th^ percentile) G1 (N = 30): 33(25, 45) G2 (N = 40): 33(25, 40) | 6 Months: P = NS (MI and LOCF)
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | SWN NR | 6 Months: P = NS (MI and LOCF)
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | Time to first readmission NA | Kaplan-Meier survival proportion estimated from graph: 100 days follow-up: G1 (N = 30): 0.9 G2 (N = 40): 0.7 200 days follow-up: G1 (N = 30): 0.7 G2 (N = 40): 0.5 300 days follow-up: G1 (N = 30): 0.6 G2 (N = 40): 0.4 365 days follow-up: G1 (N = 30): 0.55 G2 (N = 40): 0.35 P = .049
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | Occupancy of hospital beds NA | 12 Months: P = NS
Skarsholm et al, 2014^49^ G1: 30 G2: 40 | Adult inpatients close to discharge 23-70 with a diagnosis of schizophrenia or schizoaffective disorder under the care of a community mental health team. Community mental health in Denmark | | G1: NA G2: Six individual face-to-face sessions and 3 booster sessions 30-45 minutes in length. | UKU – Side Effects NA | 6 Months: #(%) G1 (N = 30): 21(70%) G2 (N = 40): 17(43%) P = .03
Other Multicomponent
Bechdolf et al, 2005^44^ G1: 40 G2: 48 | Adult inpatients 18-64 years who met criteria for a schizophrenic or related disorder Hospital in Germany | G1: Group CBT included MI, coping strategies, problem solving, relapse prevention, and focused on the treatment of auditory hallucinations and delusions, associated symptoms, relapse prevention, and med adherence. G2: Group psychoeducation focused on improvements in medication compliance and rehospitalization rates and included MI | G1: 16 group sessions over 8 weeks lasting 60-90 minutes. G2: 8 sessions in 8 weeks lasting 60-90 minutes | PANSS M(SD) Positive Scale: G1 (N = 40): 14.7(4.9) G2 (N = 48): 14.4(5.1) Negative Scale: G1 (N = 4): 16.5(6.1) G2 (N = 48): 15.5(6.0) General Score: G1 (N = 48): 33.7(9.1) G2 (N = 40): 29.6(7.6) | Post-treatment: M(SD) Positive Score: G1 (N = 37): 13.34.8) G2 (N = 43): 10.4(2.1) Negative Score: G1 (N = 37): 13.9(4.5) G2 (N = 43): 12.5(5.2) General Score: G1 (N = 38): 31.7(9.9) G2 (N = 43): 24.1(4.9) | 24 Months: M(SD) Positive Scale: G1 (N = 16): 13.5(5.6) G2 (N = 25): 13.5(6.5) F = .5, P = .49 Negative Scale: G1 (N = 16): 13.7(5.0) G2 (N = 25): 14.5(6.3) F = .001, P = .94 General Score: G1 (N = 16): 28.1(6.3) G2 (N = 25): 26.4(6.9) F = .29, P = .50
Bechdolf et al, 2005^44^ G1: 40 G2: 48 | Adult inpatients 18-64 years who met criteria for a schizophrenic or related disorder Hospital in Germany | | G1: 16 group sessions over 8 weeks lasting 60-90 minutes. G2: 8 sessions in 8 weeks lasting 60-90 minutes | Rehospitalization rates NA | NA | 24 Months: No(%) G1 (N = 16): 6(37.5%) G2 (N = 27): 16(59.3%) χ^2^ = 2.50, P = .114
Bechdolf et al, 2005^44^ G1: 40 G2: 48 | Adult inpatients 18-64 years who met criteria for a schizophrenic or related disorder Hospital in Germany | | G1: 16 group sessions over 8 weeks lasting 60-90 minutes. G2: 8 sessions in 8 weeks lasting 60-90 minutes | Length of hospitalization NA | At Discharge: G1: 92 days G2: 163 days Mann–Whitney U = 31.5, P = .224 | NA
Lee et al, 2010^61^ G1: 24 G2: 33 | Participants were outpatients between 17-60 years old, diagnosed with schizophrenia or schizoaffective disorder, and prescribed treatment with a long-acting injectable antipsychotic (depot). Community mental health in Korea | G1: Psychosocial Intervention for Relapse Prevention for depot; included psychoeducation, early warning sign detection, family education with biweekly intervention + usual care. G2: Usual care | G1: 60-minute sessions monthly for 12 months | PANSS M(SD) G1 (N = 21): 61(11) G2 (N = 25): 58.7(7.7) | Both groups experienced significant decreases (P<.01) over time, with no significant difference between groups.
Lee et al, 2010^61^ G1: 24 G2: 33 | | G1: Psychosocial Intervention for Relapse Prevention for depot; included psychoeducation, early warning sign detection, family education with biweekly intervention + usual care. G2: Usual care | G1: 60-minute sessions monthly for 12 months | CGI –SGH M(SD) G1 (N = 21): 4.1(.5) G2 (N = 25): 4.0(1.2) | Both groups experienced significant decreases (P<.01) over time, with no significant difference between groups.
Lee et al, 2010^61^ G1: 24 G2: 33 | | G1: Psychosocial Intervention for Relapse Prevention for depot; included psychoeducation, early warning sign detection, family education with biweekly intervention + usual care. G2: Usual care | G1: 60-minute sessions monthly for 12 months | GAF M(SD) G1 (N = 21): 46.4(9.8) G2 (N = 25): 45.8(14.3) | Both groups experienced significant decreases (P<.01) over time, with no significant difference between groups.
Lee et al, 2010^61^ G1: 24 G2: 33 | | G1: Psychosocial Intervention for Relapse Prevention for depot; included psychoeducation, early warning sign detection, family education with biweekly intervention + usual care. G2: Usual care | G1: 60-minute sessions monthly for 12 months | Relapse – increases to moderately severe PANSS positive score or GAF of 30 or less NA | 12 Months: N(%) G1 (N = 21): 2(9) G2 (N = 25): 10(45) P<.01 | 24 Months: N(%) G1 (N = 21): 5(24) G2 (N = 25): 12(48) P = .04
Lee et al, 2010^61^ G1: 24 G2: 33 | | G1: Psychosocial Intervention for Relapse Prevention for depot; included psychoeducation, early warning sign detection, family education with biweekly intervention + usual care. G2: Usual care | G1: 60-minute sessions monthly for 12 months | Injection discontinuation - declined to take further injections/ preferred oral medication, or when the patient no longer visited the hospital NA | Over 24 Months: N(%) G1 (N = 21): 5(23) G2 (N = 25): 18(68) χ^2^(1) = 13.0, P<.01
Lee et al, 2010^61^ G1: 24 G2: 33 | | G1: Psychosocial Intervention for Relapse Prevention for depot; included psychoeducation, early warning sign detection, family education with biweekly intervention + usual care. G2: Usual care | G1: 60-minute sessions monthly for 12 months | Treatment discontinuation - no longer visited the hospital for treatment NA | Over 24 Months: N(%) G1 (N = 21): 3(14) G2 (N = 25): 11(28) χ^2^(1) = 6.0, P = .01
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | G1: Depot + CAE is a manualized individual behavioral intervention that consists of 4 modules (psychoeducation, substance use/modified MET, provider communication, medication management). CAE is customized based on an assessment at baseline, with one to 4 modules assigned. | Eight monthly, in-person, 30- to 40-minute sessions | BPRS M(SD) G1 (N = 30): 47.1(11.5) | 13 Weeks: M(SD) G1 (N = 30): 34.0(9.0) | 25 Weeks: M(SD) G1 (N = 30): 32.8(10.0)
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | BPRS M(SD) G1 (N = 30): 47.1(11.5) | P<.001
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | PANSS M(SD) G1 (N = 13): 78.2(26.6) | Week 13: NR | Week 25: M(SD) G1 (N = 13): 51.8(16.7) P = .005
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | SOFAS M(SD) G1 (N = 19): 47.9(8.0) | 13 Weeks: NR | 25 Weeks: M(SD) G1 (N = 19): 59.3(9.8) P<.001
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | CGI –SGH M(SD) G1 (N = 18): 4.6(.9) | 13 Weeks: M(SD) G1 (N = 18): 3.5(.8) | 25 Weeks: M(SD) G1 (N = 18): 3.3(.8)
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | CGI –SGH M(SD) G1 (N = 18): 4.6(.9) | P<.001
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | Psychiatric hospitalizations M(SD) G1 (N = 17): 1.0(3.0) | 13 Weeks: NR | 25 Weeks: M(SD) G1 (N = 17): 0.1(.3)
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | Psychiatric hospitalizations M(SD) G1 (N = 17): 1.0(3.0) | | P = .13
Sajatovic et al, 2013^62^ G1: 30 | Adults 18+ with a diagnosis of schizophrenia or schizoaffective disorder who had missed 20%+ of prescribed antipsychotics and were homeless within the past 12 months. Community-based mental health | | Eight monthly, in-person, 30- to 40-minute sessions | Medical hospitalizations M(SD) G1 (N = 17): 0.1(.3) | 13 Weeks: NR | 25 Weeks: M(SD) G1 (N = 17): 0.3(.7) P = .66
Family Interventions
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | Adults 18-50 of Mexican origin and fluent Spanish speaker with a diagnosis of schizophrenia or schizoaffective disorder who had been without antipsychotic medication for at least one week in the past month without authorization, and lived with their family of origin with a relative willing to participate in family treatment. Community mental health | G1: Usual care plus Multifamily group – Adapted, a culturally modified version of multifamily group therapy, a behavioral family treatment combining psychoeducation and skills training. G2: Multifamily group – Standard plus usual care G3: Usual care | G1: Three individual family joining sessions, a 6-hour multifamily workshop, and twenty-one 90-minute multifamily group sessions twice a month. G2: Same as G1 G3: Monthly 20-minute sessions or more if participant was unstable. | BPRS NR | At the end of treatment (12 months after baseline), all 3 groups improved significantly on the BPRS relative to baseline, but there was no group X time difference (F[2,171] = 1.14,P = .32). There was no significant change in BPRS scores between the end of treatment and the 24-month follow-up in any of the 3 treatment groups.
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | | | | Time to Hospitalization NR | 4 Months: Estimated from graph G1: 75% G2: 60% G3: 60% | 8 Months: Estimated from graph G1: 72% G2: 48% G3: 45%
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | | | | Time to Hospitalization NR | 4 Months: Estimated from graph G1: 75% G2: 60% G3: 60% | 12 Months: Estimated from graph G1: 62% G2: 45% G2: 35%
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | | | | Time to Hospitalization NR | 4 Months: Estimated from graph G1: 75% G2: 60% G3: 60% | 18 Months: Estimated from graph G1: 63% G2: 38% G3: 29%
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | | | | Time to Hospitalization NR | 4 Months: Estimated from graph G1: 75% G2: 60% G3: 60% | 24 Months: Estimated from graph G1: 61% G2: 34% G3: 30%
Kopelowicz et al, 2012^50^ G1: 64 G2: 54 G3: 60 | | | | The overall test for group differences in time to first hospitalization (log-rank χ^2^ = 13.3, P = .001). Follow-up comparisons using proportional hazard regression indicated that G1 participants had longer time to first hospitalization than G2 (χ^2^ = 6.3, P = .01) and G3 (χ^2^ = 8.7, P = .003). Across the entire follow-up period, hospitalization was less likely for those in Multifamily group – Adapted (39%) than for those in Multifamily group – Standard (66%, χ^2^ = 8.2, P = .004) or TAU (70.2%, χ^2^ = 11.3, P<.001), with no differences between G2 and G3. Tests of regression show significant direct paths from treatment to hospitalization (B = -0.29, SE = 0.07, t = -3.88, P<.001), and with significant paths from G1 to adherence (B = 0.91, SE = 0.26, t = 3.53, P<.001), and G1 as a mediator between adherence and hospitalization (Sobel test = 2.92, SE = 0.033, P = .004).
Pitschel-Walz et al, 2006^51^ G1: 102 G2: 92 | Adults 18-65 with a diagnosis of schizophrenia or schizoaffective disorder Impatient wards in Germany | G1: Patients psychoeducation group focused on symptoms, etiology, acute treatment, relapse prevention, psychosocial treatment, and coping strategies. Relative psychoeducation group focused on the same as patients, and how they could best support patient. G2: Usual care | G1: Patient groups were eight 60-minute sessions, with 1-4 weekly, then 5-8 monthly. Relative groups were eight biweekly 90-minute sessions. | GAS M G1: 49 G2: 51 | Discharge: M G1: 67 G2: 64 P = NS | 12 Months: M G1: 78 G2: 68 P<.001
Pitschel-Walz et al, 2006^51^ G1: 102 G2: 92 | Adults 18-65 with a diagnosis of schizophrenia or schizoaffective disorder Impatient wards in Germany | | G1: Patient groups were eight 60-minute sessions, with 1-4 weekly, then 5-8 monthly. Relative groups were eight biweekly 90-minute sessions. | GAS M G1: 49 G2: 51 | Discharge: M G1: 67 G2: 64 P = NS | 24 Months: M G1: 75 G2: 66 P<.01
Pitschel-Walz et al, 2006^51^ G1: 102 G2: 92 | Adults 18-65 with a diagnosis of schizophrenia or schizoaffective disorder Impatient wards in Germany | | G1: Patient groups were eight 60-minute sessions, with 1-4 weekly, then 5-8 monthly. Relative groups were eight biweekly 90-minute sessions. | BPRS M G1: 41 G2: 38 P = NS | Discharge: M G1: 30 G2: 31 P = NS | 12 Months: M G1: 26 G2: 32 P<.001
Pitschel-Walz et al, 2006^51^ G1: 102 G2: 92 | Adults 18-65 with a diagnosis of schizophrenia or schizoaffective disorder Impatient wards in Germany | | G1: Patient groups were eight 60-minute sessions, with 1-4 weekly, then 5-8 monthly. Relative groups were eight biweekly 90-minute sessions. | BPRS M G1: 41 G2: 38 P = NS | Discharge: M G1: 30 G2: 31 P = NS | 24 Months: M G1: 28 G2: 34 P<.01
Pitschel-Walz et al, 2006^51^ G1: 102 G2: 92 | Adults 18-65 with a diagnosis of schizophrenia or schizoaffective disorder Impatient wards in Germany | | G1: Patient groups were eight 60-minute sessions, with 1-4 weekly, then 5-8 monthly. Relative groups were eight biweekly 90-minute sessions. | Rehospitalization within the first 2 years and days in the hospital NA | NA | 12 Months: # M(SD), Days M(SD) G1: .3(.7), 12(46.6) G2: .6(.8), 30(54.4) P = NS
Pitschel-Walz et al, 2006^51^ G1: 102 G2: 92 | Adults 18-65 with a diagnosis of schizophrenia or schizoaffective disorder Impatient wards in Germany | | G1: Patient groups were eight 60-minute sessions, with 1-4 weekly, then 5-8 monthly. Relative groups were eight biweekly 90-minute sessions. | Rehospitalization within the first 2 years and days in the hospital NA | NA | 24 Months: # M(SD), Days M(SD) G1: .6(1.1), 39(90.4) G2: 1.1(1.4), 78(127.2) #: P = .031 Days: P = .034
Valencia et al, 2010^52^ G1: 47 G2: 36 | Adult outpatients with a diagnosis of schizophrenia who were adherent to their medication and clinically stable Community mental health in Mexico | G1: Group/family (plus individual component) psychosocial skills psychoeducation including medication, decision making, relapse prevention, avoiding drug and alcohol, friendships, improving family relations + usual care G2: Usual care | G1: Patients – 90-minute group session weekly – 40 total sessions in 12 months. Family + patient – 5 sessions G2: 20-minute monthly appointments | GAF M(SD) G1 (N = 47): 42.4(5.9) G2 (N = 36): 42.7(6.1) | End of Treatment (12 Months): M(SD) G1 (N = 47): 57.6(9.4) G2 (N = 36): 44.3(9.0) There was a significant main effect for time (P<.001) and group (P<.01), and group X time (P<.01)
Valencia et al, 2010^52^ G1: 47 G2: 36 | Adult outpatients with a diagnosis of schizophrenia who were adherent to their medication and clinically stable Community mental health in Mexico | | G1: Patients – 90-minute group session weekly – 40 total sessions in 12 months. Family + patient – 5 sessions G2: 20-minute monthly appointments | PANSS M(SD) Total: G1 (N = 47): 87.0(44.5) G2 (N = 36): 76.4(35.5) Positive: G1 (N = 47): 19.1(12.3) G2 (N = 36):15.8(9.6) Negative: G1 (N = 47): 23.2(12.1) G2 (N = 36): 20.6(9.8) General Psychopathology: G1 (N = 47): 44.8(21.7) G2 (N = 36): 40.1(17.5) | End of Treatment (12 Months): M(SD) Total: G1 (N = 47): 51.8(12.1) G2 (N = 36): 57.3(17.7 Positive: G1 (N = 47): 8.6(2.4) G2 (N = 36): 11.4(4.7) Negative: G1 (N = 47): 11.2(5.2) G2 (N = 36): 14.9(6.6) General Psychopathology: G1 (N = 47): 22.0(5.6) G2 (N = 36): 30.9(8.9) There was a significant main effect for time for all scales and total (all Ps<.001). There was a significant group X time interaction: Total: P<.001 Positive: P<.01 Negative: P<.001 General Psychopathology: P<.01
Valencia et al, 2010^52^ G1: 47 G2: 36 | Adult outpatients with a diagnosis of schizophrenia who were adherent to their medication and clinically stable Community mental health in Mexico | | G1: Patients – 90-minute group session weekly – 40 total sessions in 12 months. Family + patient – 5 sessions G2: 20-minute monthly appointments | LEE M(SD) G1 (N = 44): 62.32(12.31) G2 (N = 34): 64.71(13.2) | End of Treatment (12 Months): M(SD) G1 (N = 44): 58.59 G2 (N = 34): 62.0(10.95) P<.05
Valencia et al, 2010^52^ G1: 47 G2: 36 | Adult outpatients with a diagnosis of schizophrenia who were adherent to their medication and clinically stable Community mental health in Mexico | | G1: Patients – 90-minute group session weekly – 40 total sessions in 12 months. Family + patient – 5 sessions G2: 20-minute monthly appointments | Rehospitalization NA | End of Treatment (12 Months): G1: 2.1% G2: 14% P<.05
Valencia et al, 2010^52^ G1: 47 G2: 36 | Adult outpatients with a diagnosis of schizophrenia who were adherent to their medication and clinically stable Community mental health in Mexico | | G1: Patients – 90-minute group session weekly – 40 total sessions in 12 months. Family + patient – 5 sessions G2: 20-minute monthly appointments | Relapse - defined as a significant exacerbation of psychotic symptoms with at least a 25% increase on the PANSS total score from baseline NA | End of Treatment (12 Months): G1: 12.8% G2: 33.3% P<.05
Motivational Interviewing(MI)
Barkhof et al, 2013^58^ G1: 55 G2: 59 | Adults with schizophrenia or schizoaffective disorder with a psychotic relapse or deterioration following non- adherence to antipsychotics, who have resumed antipsychotics with some clinical improvement. 3 sites - Inpatient and outpatients in Amsterdam | G1: A manualized MI intervention based on negative symptoms, positive symptoms, cognitive deficits. G2: Health education on general health topics. | Eight individual 20- to 45-minute sessions over 26 weeks. | Hospitalized # M(SD) G1 (N = 55): 24(44%) G2 (N = 59): 25(44%) | 26 Weeks: # M(SD) G1 (N = 45): 17(38) G2 (N = 49): 19(39%) | 6 Months: # M(SD) G1 (N = 45): 12(27%) G2 (N = 48): 19(40)
Barkhof et al, 2013^58^ G1: 55 G2: 59 | | G1: A manualized MI intervention based on negative symptoms, positive symptoms, cognitive deficits. G2: Health education on general health topics. | Eight individual 20- to 45-minute sessions over 26 weeks. | There were no significant differences by intervention at any time point. In participants 35 and under, fewer in the MI group (3/21, 14% vs 11/22, 50%) were hospitalized over the 6-month period (P = .012)
Barkhof et al, 2013^58^ G1: 55 G2: 59 | | G1: A manualized MI intervention based on negative symptoms, positive symptoms, cognitive deficits. G2: Health education on general health topics. | Eight individual 20- to 45-minute sessions over 26 weeks. | PANSS M(SD) Total Score: G1 (N = 30): 72(17.9) G2 (N = 32): 72(17.5) Positive Symptoms: G1 (N = 30): 16.2(5.87) G2 (N = 32): 17.2(6.69 Negative Symptoms: G1 (N = 30): 18.7(5.8) G2 (N = 32): 19.1(6.56) General Symptoms: G1 (N = 30): 37.7(9.74) G2 (N = 32): 35.8(8.28) | 26 Weeks: M(SD) Total Score: G1 (N = 30): 65.6(22.0) G2 (N = 32): 63.5(16.9) Positive Symptoms: G1 (N = 30): 15.2(6.29) G2 (N = 32): 15.0(6.05) Negative Symptoms: G1 (N = 30): 16.0(5.83) G2 (N = 32): 16.4(6.53) General Symptoms: G1 (N = 30): 35.4(12.98) G2 (N = 32): 32.2(7.07) | 6 Months: M(SD) Total Score: G1 (N = 30): 64.0(30.3) G2 (N = 32): 66.2(16.7) Positive Symptoms: G1 (N = 30): 15.7(8.84) G2 (N = 32): 15.9(6.32) Negative Symptoms: G1 (N = 30): 16.2(7.31) G2 (N = 32): 17.3(6.66) General Symptoms: G1 (N = 30): 32.1(14.33) G2 (N = 32): 32.2(7.89)
Barkhof et al, 2013^58^ G1: 55 G2: 59 | | G1: A manualized MI intervention based on negative symptoms, positive symptoms, cognitive deficits. G2: Health education on general health topics. | Eight individual 20- to 45-minute sessions over 26 weeks. | For all subscales P = NS
Barkhof et al, 2013^58^ G1: 55 G2: 59 | | G1: A manualized MI intervention based on negative symptoms, positive symptoms, cognitive deficits. G2: Health education on general health topics. | Eight individual 20- to 45-minute sessions over 26 weeks. | There was no significant interaction between type of intervention and time (P = .68), with a large effect for time with both groups showing reductions in the severity of psychopathology (F(2, 110) = 5.59, P = .005, but no differences between interventions (P = .99). Female patients showed a larger decrease than males in reduction of general PANSS symptoms in G1 (Δ 7.9, SD = 4.0) compared with the HE group (Δ 3.4, SD = 2.4); t (11) = −2.40, P = .035.
Shared Decision-making
Hamann et al, 2007^59^ G1: 39 G2: 47 | Adult inpatients 18-65 with a diagnosis of schizophrenia or schizophreniform disorder Hospital in Germany | G1: Decision aid booklet covering pros/cons of medication, psychoeducation, interventions + usual care G2: Usual care | G1: Decision aid session with nurse and extra planning talk with psychiatrist | CGI NR | NR | 18 Months: M(SD) G1 (N = 35): 4.0(1.5) G2 (N = 40): 4.1(1.4) P = NS
Hamann et al, 2007^59^ G1: 39 G2: 47 | Adult inpatients 18-65 with a diagnosis of schizophrenia or schizophreniform disorder Hospital in Germany | G1: Decision aid booklet covering pros/cons of medication, psychoeducation, interventions + usual care G2: Usual care | G1: Decision aid session with nurse and extra planning talk with psychiatrist | GAF NR | NR | 18 Months: M(SD) G1 (N = 30): 54.7(16.5) G2 (N = 37): 51.0(18.5) P = NS
Hamann et al, 2007^59^ G1: 39 G2: 47 | Adult inpatients 18-65 with a diagnosis of schizophrenia or schizophreniform disorder Hospital in Germany | G1: Decision aid booklet covering pros/cons of medication, psychoeducation, interventions + usual care G2: Usual care | G1: Decision aid session with nurse and extra planning talk with psychiatrist | Rehospitalization NA | 6 Months: #(%) G1 (N = 36): 8(22) G2 (N = 37): 8(22) P = NS | 18 Months: #(%) G1 (N = 38): 20(53) G2 (N = 41): 19(46) P = NS
Hamann et al, 2007^59^ G1: 39 G2: 47 | Adult inpatients 18-65 with a diagnosis of schizophrenia or schizophreniform disorder Hospital in Germany | G1: Decision aid booklet covering pros/cons of medication, psychoeducation, interventions + usual care G2: Usual care | G1: Decision aid session with nurse and extra planning talk with psychiatrist | Rehospitalization NA | In a backwards stepwise regression, having received the intervention showed a positive trend (OR = .19, P = .08) in the direction of fewer hospitalizations.
Cognitive Adaptation Therapy (CAT)
Velligan et al, 2008^60^ G1: 37 G2: 32 G3: 29 | Adult outpatients 18-60 diagnosed with schizophrenia and prescribed an oral antipsychotic Community mental health | G1: CAT consists of manualized individualized strategies and environmental supports designed to include medication adherence, grooming, and activities of daily living G2: Pharm-CAT consisted of only the medication adherence components of CAT G3: Usual care | G1: Individual face-to-face weekly visits lasting 30-45 minutes for 9 months G2: Same as G1, but sessions were generally shorter | BPRS–E NR | Results of a mixed-effects regression model with the base- line symptom scores used as covariates yielded no significant main effects or interactions (all Ps>.09).
Velligan et al, 2008^60^ G1: 37 G2: 32 G3: 29 | Adult outpatients 18-60 diagnosed with schizophrenia and prescribed an oral antipsychotic Community mental health | | G1: Individual face-to-face weekly visits lasting 30-45 minutes for 9 months G2: Same as G1, but sessions were generally shorter | Relapse – index based on BPRS psychosis items, suicidality, hospitalization, inability to care for self unsupervised NR | The time to relapse differed by group ( χ (2)/(( 2 )) = 11.09 ; P<.004). G1 vs G3: χ^2^ = 8.29; P<.004 G2 vs G3: χ^2^ = 8.20; P<.005, respectively). Over 65% of patients in G1 and G2 survived the 15 months without a relapse vs only 19% of G3. There were no differences between G1 and G2.
Velligan et al, 2008^60^ G1: 37 G2: 32 G3: 29 | Adult outpatients 18-60 diagnosed with schizophrenia and prescribed an oral antipsychotic Community mental health | | G1: Individual face-to-face weekly visits lasting 30-45 minutes for 9 months G2: Same as G1, but sessions were generally shorter | SOFAS NR | G2 was higher functioning than G3 at 3 and 6 months (P's<.05) but not at any time point thereafter. G1 was significantly higher functioning than G3 at all assessment points during the treatment period (all P's<.0001), and significantly better than G1 in the first 3 months of follow-up (P<.0001), but there was only a nonsignificant positive trend by the end of 6-month follow-up. G1 was significantly better than G2 at all time points (P's <.0004) with the exception of the 6-month follow-up. Effect sizes for G1 were large during the treatment phase and moderate 6 months after withdrawal of home visits. The effect size for G2 was small.
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | G1: Pharm-CAT consists of manualized individualized strategies and environmental supports targeting medication adherence G2: Med-eMonitor (MM) is a smart pill container capable of cueing and warning patients, recording side effect complaints, alerting staff of failure to take medication as prescribed. G3: Usual care | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | Hospital and emergency services contact NA | There were no differences between groups (χ^2^ = 0.53, P = .77).
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | BPRS–E | There were no significant main effects or interactions (all P values >.09).
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | SOFAS | There were no significant main effects or interactions (all P values >.09).
Pharmacy Interventions
Kavanagh et al, 2003^53^ G1: 15 G2: 15 | Adults diagnosed with psychotic disorders who were inpatients in a psychiatric ward. Hospital in London | G1: Pharmacist-led psychoeducation group including Q & A about medication, rationale, risks of stopping, side effects, risk/benefit evaluations. One session focused on antipsychotics, the second session focused on mood stabilizers + usual care. G2: Usual care | G1: Two one-hour group sessions on consecutive weeks. | SAI-E M(SD) G1 (N = 15): 3.60(4.88) G2 (N = 15): 2.67(5.81) P = NS | Post Session and 2 Weeks Follow-up: There was no main effect.
Kavanagh et al, 2003^53^ G1: 15 G2: 15 | Adults diagnosed with psychotic disorders who were inpatients in a psychiatric ward. Hospital in London | | G1: Two one-hour group sessions on consecutive weeks. | BPRS M(SD) G1 (N = 15): 36.47(2.77) G2 (N = 15): 28.87(4.05) F = 11.843, P = .004 | Post Session and 2 Weeks Follow-up: There was no main effect of time and no significant time X group interaction.
Technology Interventions (e-Monitoring, SMS, Phone)
Beebe et al, 2014^54^ G1: 10 G2: 10 G3: 10 | Adults 21-68 with a diagnosis of schizophrenia or schizoaffective disorder receiving outpatient care. Community mental health | G1: TIPS + Text. TIPS is a manualized intervention providing weekly telephone support addressing taking medication, attending appointments, coping with symptoms, abstaining from alcohol and other drugs, and getting along with others. G2: TIPS only G3: Text only – text format of the TIPS protocol. Texts were delivered daily | G1: Weekly phone calls and daily texts for 3 months G2: Weekly phone calls for 3 months G3: Daily text messages for 3 months | BPRS M(SD) G1 (N = 10): 37.7(6.1) G2 (N = 10): 50.1(11.7) G3 (N = 10): 41.3(5.2) | 1 Month: M(SD) G1 (N = 10): 38.2(11.9) G2 (N = 10): 38.5(9.1) G3 (N = 10): 31.8(9.7) | 2 Months: M(SD) G1 (N = 10): 36.8(10.9) G2 (N = 10): 47.6(9.5) G3 (N = 8): 46.5(10.9) 3 Months: M(SD) G1 (N = 10): 35.8(12.8) G2 (N = 10): 41.7(12.4) G3 (N = 8): 44.5(11.6)
Beebe et al, 2014^54^ G1: 10 G2: 10 G3: 10 | Adults 21-68 with a diagnosis of schizophrenia or schizoaffective disorder receiving outpatient care. Community mental health | | G1: Weekly phone calls and daily texts for 3 months G2: Weekly phone calls for 3 months G3: Daily text messages for 3 months | Analyses yielded a statistically significant main effect for group (F (4,26) = 4.2, P = .005, with mean G1 scores lower than G3 (average mean difference of 9.2 points) at 2 of 3 post-intervention measurement points. Mean G1 scores were lower than G2 scores (average mean difference of 5.7 points) at months 1, 2, 3.
Frangou et al, 2005^55^ G1: 36 G2: 36 G3: 36 | Adult outpatients 18-64 with a diagnosis of schizophrenia who had at least 2 admissions in preceding 12 months, and prescribed oral medication. Community mental health in London | G1: e-monitoring (MEMS) – provided with a medication dispenser that recorded access and transmitted data via the @HOME platform. Staff was alerted if participant took less than prescribed amount. G2: Pill counting by pharmacists at study visits G3: Self-report of adherence using Morisky scale. | G1: eMonitoring G2: Pharmacist G3: Self-report | CGI –SGH M(SD) G1 (N = 36): 3.1(1) G2 (N = 36): 3.0(1.1) G3 (N = 36): 3.1(1) | 8 Weeks: M(SD) G1 (N = 36): 2.1(1.6) G2 (N = 36): 2.5(1) G3 (N = 36): 3.3(1.2) P = .008, G1 significantly better than G2 (P = .04) and G3 (P = .01). G2 also significantly better than G3 (P = .05)
Frangou et al, 2005^55^ G1: 36 G2: 36 G3: 36 | Adult outpatients 18-64 with a diagnosis of schizophrenia who had at least 2 admissions in preceding 12 months, and prescribed oral medication. Community mental health in London | | G1: eMonitoring G2: Pharmacist G3: Self-report | PANSS M(SD) G1 (N = 36): 43(14.9) G2 (N = 36): 43.4(15.5) G3 (N = 36): 46.6(15.9) | 8 Weeks: M(SD) G1 (N = 36): 28.1(2) G2 (N = 36): 28.3(13.1) G3 (N = 36): 42.7(21.4) P = .004, G3 less improved compared to G1 (P = .04) and G2 (P = .008). No difference between G1 and G2
Frangou et al, 2005^55^ G1: 36 G2: 36 G3: 36 | Adult outpatients 18-64 with a diagnosis of schizophrenia who had at least 2 admissions in preceding 12 months, and prescribed oral medication. Community mental health in London | | G1: eMonitoring G2: Pharmacist G3: Self-report | Resource utilization – total number of psychiatric and CPN contacts, and emergency visits M(SD) Psychiatric: G1 (N = 36): 2.1(.7) G2 (N = 36): 2.2(.8) G3 (N = 36): 2.2(1.2) CPN: G1 (N = 36): 8.5(2.6) G2 (N-36): 8.5(2.1) G3 (N = 36): 8.3(2.7) Emergency department visits: G1 (N = 36): .6(.7) G2 (N = 36): .5(.6) G3 (N = 36): .5(.8) | 8 Weeks: M(SD) Psychiatric: G1 (N = 36): 1.7(.6) G2 (N = 36): 2.1(.6) G3 (N = 36): 2.2(.8) CPN: G1 (N = 36): 7.4(1.2) G2 (N = 36): 8.0(1.6) G3 (N = 36): 8.1(2.0) Emergency department visits : G1 (N = 36): .1(.3) G2 (N = 36): .9(.9) G3 (N = 36): .8(1.0) MANOVA: P = .002 Significantly fewer psychiatric and emergency department visits for G1 (G2, P = .01; G3, P = .0001).
Montes et al, 2012^56^ G1: 100 G2: 154 | Adult outpatients 18-65 with a diagnosis of schizophrenia who were clinically stable, prescribed a single antipsychotic, and one affirmative answer on the MAQ Community mental health in Spain | G1: Daily SMS reminders to take their medication, “Please remember to take your medication.” + usual care G2: Usual care | G1: Daily SMS for 3 months | CGI –SGH M(95% CI) Severity: Positive: G1 (N = 100): 2.5(2.24 to 2.76) G2 (N = 154): 2.8(2.61 to 2.99) Negative: G1 (N = 100): 3.3(3.06 6o 3.54) G2 (N = 154): 3.4(3.22 to 3.58) Depressive: G1 (N = 100): 2.3(2.06 to 2.54) G2 (N = 154): 2.3(2.11 to 2.49) Cognitive: G1 (N = 100): 2.8(2.58 to 3.02) G2 (N = 154): 3.0(2.84 to 3.16) Global: G1 (N = 100): 3.0(2.78 to 3.22) G2 (N = 154): 3.2(3.06 to 3.34) Degree of Change: NR | 3 Months: Mean changes M(95% CI) Severity: Positive: G1: -.4(-.42 to -.38) G2: -.3(-.32 to -.28) P = .26 Negative: G1: -.4(-.42 to -.38) G2: -.3(-.32 to -.28) P = .16 Depressive: G1: -.2(.22 to -.18) G2: -.1(-.12 to -.08) P = .09 Cognitive: G1: -.4(-.42 to -.38) G2: -.3(-.32 to -.28) P = .13 Global: G1: -.5(-.52 to -.48) G2: -.3(-.32 to -.28) P = .11 Degree of Change: Positive: G1: 3.2(3.0 to 3.4) G2: 3.4(3.24 to 3.56) P = .1 Negative: G1: 3.3(3.10 to 3.50) G2: 3.5(3.36 to 3.64) P = .02 Depressive: G1: 3.3(3.10 to 3.50) G2: 3.5(3.34 to 3.66) P = .07 Cognitive: G1: 3.3(3.12 to 3.48) G2: 3.6(3.46 to 3.74) P = .01 Global: G1: 3.2(3.02 to 3.38) G2: 3.5(3.36 to 3.64) P = .012 | 6 Months: Mean changes M(95% CI) Severity: Positive: G1: 3(-.32 to -.28) G2: 3(-.32 to -.28) P = .89 Negative: G1: -.6(-.62 to -.58) G2: 3(-.32 to -.28) P = .03 Depressive: G1: -.2(.22 to -.18) G1: -.1(-.11 to -.08) P = .35 Cognitive: G1: -.4(-.42 to -.38) G2: -.3(-.32 to -.28) P = .48 Global: G1: -.5(-.52 to -.48) G2: -.4(-.42 to -.38) P = .48 Degree of Change: Positive: G1: 3.4(3.38 to 3.42) G2: 3.3(3.14 to 3.46) P = .63 Negative: G1: 3.4(3.38 to 3.42) G2: 3.4(3.24 to 3.56) P = .82 Depressive: G1: 3.4(3.38 to 3.42) G2: 3.4(3.22 to 3.58) P = .88 Cognitive: G1: 3.5(3.48 to 3.52) G2: 3.5(3.34 to 3.66) P = .8 Global: G1: 3.3(3.10 to 3.50) G2: 3.5(3.32 to 3.68) P = .32
Montes et al, 2012^56^ G1: 100 G2: 154 | Adult outpatients 18-65 with a diagnosis of schizophrenia who were clinically stable, prescribed a single antipsychotic, and one affirmative answer on the MAQ Community mental health in Spain | G1: Daily SMS reminders to take their medication, “Please remember to take your medication.” + usual care G2: Usual care | G1: Daily SMS for 3 months | EQ-5D M(95% CI) G1 (N = 100): 65.9(62.5 to 69.2) G2 (N = 154): 64.3(61.7 to 66.8) | 3 Months: Mean changes M(95% CI) G1: 6.6(6.3 to 6.8) G2: 3.1(2.91 to 3.29) P = .03 | 6 Months: Mean changes M(95% CI) G1: 6.1(5.84 to 5.36) G2: 5.6(5.42 to 5.78) P = .75
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | G1: Pharm-CAT consists of manualized individualized strategies and environmental supports targeting medication adherence G2: Med-eMonitor (MM) is a smart pill container capable of cueing and warning patients, recording side effect complaints, alerting staff of failure to take medication as prescribed. G3: Usual care | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | Hospital and emergency services contact NA | There were no differences between groups (χ^2^ = 0.53, P = .77).
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | BPRS–E | There were no significant main effects or interactions (all P values >.09).
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | SOFAS | There were no significant main effects or interactions (all P values >.09).

Note. Studies were conducted in the US unless otherwise specified. Studies comparing interventions may be represented in the table more than once. Brief descriptions of patient outcome assessments are reported in Appendix F.

Abbreviations: BPRS = Brief Psychiatric Rating Scale ; BPRS–E = Brief Psychiatric Rating Scale – Expanded; CAE = Customized adherence enhancement; CAT = Cognitive Adaptation Training; CBT = Cognitive behavioral therapy; CGI = Clinical Global Impression scale; CGI-SGH = Clinical Global Impression – Schizophrenia scale; EQ-5D = EuroQoL; GAF = Global Assessment of Functioning; GAS = Global Assessment Scale; LEE = Level of Expressed Emotion; M = Mean; MAQ = Medication Adherence Questionnaire; MET = Motivational Enhancement Therapy; MM = Med-eMonitor; PANSS = Positive and Negative Syndrome Scale; QLF = Quality of Life Scale; SAI = Schedule for Assessment of Insight; SAI-E = Schedule for Assessment of Insight- Expanded; SD = Standard deviation; SF-36 = Short Form Health Survey; SOFAS = Social and Occupational Functioning Scale; SWN = Subjective Well-being on Neuroleptic Treatment Scale; TIPS = Telephone Intervention Problem Solving for Schizophrenia.

Table 11 Costs Associated with Medication Adherence Interventions

Study; N per Group | Sample and Setting | Intervention Groups | Intervention Intensity | Measure (range, direction) | Source | Baseline | First Follow-up | Additional Follow-ups
Healey et al, 1998^42^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | G1: Routine management plus Compliance Therapy, a combination of MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. G2: Routine management plus supportive counseling (no medication issues addressed) | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | Client Service Receipt Inventory (CSRI), which measures the frequency and duration of service contacts. | Self-report information, supplemented case note and agency data, including hospital admission records | 3 months pre-entry: £ Mean/MDN (SD) G1 (N = 37): 113/27 (184) G2 (N = 35): 188/42 (131) | 6 Months: £ Mean/MDN(SD) G1 N = 36): 187/49 (292) G2 (N = 34): 252/230(234) P = .146 | 12 Months: £ Mean/MDN(SD) G1 (N = 33): 232/161 (281) G2 (N = 34) 177/230(278) P = .216
Healey et al, 1998^42^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | Client Service Receipt Inventory (CSRI), which measures the frequency and duration of service contacts. | Self-report information, supplemented case note and agency data, including hospital admission records | 3 months pre-entry: £ Mean/MDN (SD) G1 (N = 37): 113/27 (184) G2 (N = 35): 188/42 (131) | 6 Months: £ Mean/MDN(SD) G1 N = 36): 187/49 (292) G2 (N = 34): 252/230(234) P = .146 | 18 Months: £ Mean/MDN(SD) G1 (N = 24): 239/161(281) G2 (N = 21): 326/146(404) P = .468
Healey et al, 1998^42^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | Client Service Receipt Inventory (CSRI), which measures the frequency and duration of service contacts. | Self-report information, supplemented case note and agency data, including hospital admission records | 3 months pre-entry: £ Mean/MDN (SD) G1 (N = 37): 113/27 (184) G2 (N = 35): 188/42 (131) | 6 Months: £ Mean/MDN(SD) G1 N = 36): 187/49 (292) G2 (N = 34): 252/230(234) P = .146 | When comparing Months 1-18: £ Mean/MDN(SD) G1 (N = 23): 175/146(148) G2 (N = 18) 193/152(222) P = .920
Healey et al, 1998^42^ G1: 39 G2: 35 | Adult inpatients with psychotic disorders Hospital in England | | Four to 6 individual face-to-face sessions (M = 4.7) lasting 20-60 minutes twice weekly | Client Service Receipt Inventory (CSRI), which measures the frequency and duration of service contacts. | Self-report information, supplemented case note and agency data, including hospital admission records | Statistically significant positive correlations were found for the entire sample between (a) costs and changes in compliance, and (b) costs and changes in insight between one and 6 months. When the Compliance Therapy and control groups were analyzed separately, neither revealed an obvious efficiency advantage in terms of translating service inputs into subject outcomes. A positive association was found for G1 between change in compliance and costs over 1-6 months (P = .004) and change in insight and costs over the same period (P = .022). The only other significant correlation was between residual costs and change in compliance in the control group over the 7-12 month period (P = .023).
Velligan et al, 2013^57^ G1: 47 G2: 48 G3: 47 | Adults 18-60 diagnosed with schizophrenia or schizoaffective disorder treated with oral antipsychotic(s) who had missed at least one dose in the previous week. Community mental health | G1: Pharm-CAT consists of manualized individualized strategies and environmental supports targeting medication adherence G2: Med-eMonitor (MM) is a smart pill container capable of cueing and warning patients, recording side effect complaints, alerting staff of failure to take medication as prescribed. G3: Usual care | G1: Home visits 30 minutes long weekly for 9 months. G2: MM support and phone contact as needed. | Average cost of treatment per patient per month included mileage for home visits, monitor, web support, Pharm-CAT staff and supplies. | Multiple | NA | Average cost of treatment per patient per month G1: $180 G2: $130

Note. Studies were conducted in the US unless otherwise specified. Brief descriptions of patient outcome assessments are reported in Appendix F.

Abbreviations: CAT = Cognitive Adaptation Training; MDN = Median; MI = Motivational interviewing; MM = Med-eMonitor.

Studies were conducted in community mental health outpatient settings (12 studies) and in hospitals with inpatients (4 studies), with other interventions spanning pre- and post-discharge periods (3 studies), and one multi-site study that included both inpatient and outpatient settings. Six studies were conducted in the US and 12 were conducted in Europe, with one study conducted in South Korea, and another in Mexico. The included studies measured adherence using objective measures such as e-monitoring/MEMS, pill counts, and blood plasma concentration levels; validated scales measuring adherence such as the Medication Adherence Questionnaire (MAQ), the Medication Adherence Rating Scale (MARS), and the Drug Attitude Inventory (DAI), which has been shown to correlate with other measures of adherence;^1^ and a variety of other measures of adherence, some of which used multiple sources. The patient outcomes most frequently reported were positive and negative symptoms, symptom severity, functional impairment, and time to first readmission or hospitalization. Commonly used measures included the Positive and Negative Syndrome Scale (PANSS), the Clinical Global Impression scale (CGI), the Brief Psychiatric Rating Scale (BPRS), and the Global Assessment of Functioning (GAF). Tables 4-11 provide study detail, and a brief description of adherence and patient outcome measures are provided in Appendices E and F.

### 1a What are the effects of medication adherence interventions on psychopharmacological adherence?

#### Multicomponent Behavioral Interventions

Summary: Findings of the included studies are mixed, and there is no consistent evidence from which to draw conclusions about the efficacy of multicomponent behavioral interventions on pharmacological adherence. Table 4 provides study detail.

Details: There are a wide range of behavioral interventions targeting medication adherence, including functional analysis (eg, identifying the antecedents to specific behaviors), positive reinforcement, relaxation techniques. CBT combines behavioral interventions with the identification and challenging of cognitive distortions (eg, overgeneralization, black and white thinking). Other interventions commonly combined into multicomponent interventions include psychoeducation and MI, a non-confrontational goal-oriented style focused on overcoming ambivalence related to behavior change. Compliance Therapy is a multicomponent intervention first studied by Hayward et al in 1995^63^ and described fully in a manual by Kemp et al in 1997^64^ that combines MI, cognitive, and psychoeducation approaches targeting psychotic symptoms, focusing on illness and treatment history, beliefs and understanding of the illness, and ambivalence towards treatment and stigma. Adherence Therapy^65^ is a manualized intervention that builds on Compliance Therapy, and is a patient-centered cognitive behavioral approach incorporating MI and emphasizing joint decision-making, medication problem solving, exploring ambivalence, and the discussion of beliefs and concerns about medication.

We identified 7 studies (2 high ROB,^43,45^ 3 moderate ROB,^44,47,49^ 2 low ROB^46,48^) examining multicomponent behavioral interventions, of which 2 examined Adherence Therapy. The first was an RCT examining clinically unstable outpatients and found that over a period of 12 months, there was no difference between Adherence Therapy and the health education controls.^46^ The second study, also an RCT, included 5 sessions while participants were inpatients, and 3 sessions after release. At 12 weeks post-discharge, there was no difference in medication adherence between the Adherence Therapy group and controls.^48^

Four studies examined Compliance Therapy with mixed findings. A prospective cohort study conducted in a community setting found a significant improvement in adherence between baseline and the end of treatment (1 month) as assessed using the MARS; however, there was no significant improvement by 6 months follow-up, and no significant improvement as assessed using MEMS at either time point.^45^ An RCT of inpatients compared Compliance Therapy to supportive counseling, and found significantly better adherence in the Compliance Therapy group at discharge, with differences between the 2 groups continuing through the 18-month follow-up period.^43^ Two studies however, found no significant improvement in medication adherence associated with Compliance Therapy.^47,49^

Finally, one RCT of inpatients compared group CBT with MI to group psychoeducation with MI and found no difference between groups at 24 months follow-up.^44^ Table 4 provides study detail.

#### Interventions Involving Family Members

Summary: Findings of the included studies show a generally positive effect associated with interventions for medication adherence involving family members.

Details: Interventions involving family members are often conducted in group settings, and often include psychoeducation, support for families, behavioral problem solving, and crisis management.^66^

Three RCTs (all moderate ROB) meeting inclusion criteria examined the effect of interventions involving family members.^50-52^ Two studies included both an individual and a family component, with individual treatment conducted in a group setting.^51,52^ Two studies involved interventions that included both the participant and family together,^50,52^ with one study including a group intervention for relatives only.^51^ Two studies found family interventions to be more effective than usual care,^51,52^ and one study found no significant difference when controlling for time.^50^ Table 5 provides study detail.

#### System-level Interventions

Summary: There is insufficient evidence regarding the efficacy of system-level interventions to improve medication adherence.

Details: System-level interventions include policies implemented at the system-level for all patients meeting predefined criteria, and may include screening, education, and other interventions.

One included RCT (moderate ROB) compared a system-level intervention to Compliance Therapy.^49^ The system-level intervention included a brochure and questionnaire on antipsychotic treatment as a basis for conversation between participant/provider, a screening form for identification of compliance problems as the basis for participant/nurse conversation, a reminder box that contained medicine cards, dosage boxes, electronic alarm systems, medication reconciliation, and the requirement that providers adhere to clinical guidelines. Although the system-level group showed better adherence outcomes, differences were not significant. Table 6 provides study detail.

#### Pharmacist-led Interventions

Summary: Findings of the included studies are insufficient to determine the efficacy of pharmacist-led interventions.

Details: Pharmacist-led interventions are often brief interventions focused on education specific to medication, including the benefits, side effects, and potential consequences for discontinuing medication.

We identified one study (high ROB) examining a pharmacist-led intervention, which involved a group session that included a question and answer session about medication, rationale, risks of stopping, side effects, risk/benefit evaluations.^53^ One session focused on antipsychotics, the second session focused on mood stabilizers. There was no significant difference between the pharmacist-led intervention and usual care. Table 6 provides study detail.

#### Technology Interventions

Summary: Findings of the included studies show a generally positive effect, with low strength of evidence.

Details: Technology interventions vary, and may include SMS or telephone reminders, e-monitoring using a variety of platforms, including MEMS caps, which record the time and date each time the cap is opened.^54^

We identified 4 studies (one high ROB,^55^ 2 moderate ROB,^54,56^ one low ROB^57^) examining technology interventions to improve psychopharmacologic adherence. Two RCTs compared e-monitoring to a variety of comparators.^55,57^ One study found significantly better adherence when assessed using the e-monitor as compared with usual care, but not as assessed by pill counts.^57^ The second study, which examined e-monitoring both as an intervention and a measure of adherence, compared adherence measured by e-monitoring, pill counts, and self-report using a validated scale, and found adherence in the e-monitoring group to be significantly higher than both pill counts by a pharmacist and self-report.^55^ The third study compared a telephone and SMS intervention to telephone only and SMS only. Results indicated that although adherence was better in the group receiving both phone and SMS, the differences were not significant, nor did adherence improve significantly for any of the groups over the duration of the study.^54^ The fourth study compared daily SMS to usual care, and found significantly better adherence in the intervention group both at the end of the active phase (3 months) and at 6-months follow-up.^56^ Table 6 provides more details about the included studies.

#### Other Interventions

Summary: Findings are insufficient to evaluate the efficacy of other interventions for psychopharmacologic adherence in patients along the psychotic spectrum.

Details: Four studies (one high ROB,^59^ one moderate ROB,^60^ 2 low ROB^57,58^) examined other interventions for medication adherence for people along the psychotic spectrum. Included studies examined MI, shared decision making, and Cognitive Adaptation Therapy (CAT). One study examined an MI intervention targeting positive and negative symptoms and cognitive deficits.^58^ Results indicated no significant difference between the intervention and comparison group, with better adherence in patients prescribed depot antipsychotics regardless of group. A second study examined a shared decision intervention that included a shared decision aid booklet covering pros/cons of medication, psychoeducation, and a treatment agreement with their clinician.^59^ No difference in adherence was found as compared to usual care. Two studies examined CAT, an intervention focused on individualized strategies and environmental supports – one comparing standard CAT to the medication adherence component of CAT alone (Pharm-CAT) and usual care,^60^ and the other comparing Pharm-CAT to e-monitoring and usual care.^57^ Results indicated no difference between CAT and Pharm-CAT, and that both CAT and Pharm-CAT resulted in better adherence than usual care through 15 months as evaluated by pill counts. The study also found CAT, but not Pharm-CAT, to be better than usual care over 15 months as evaluated by pharmacy refill rates.^60^ There were no differences between Pharm-CAT and e-monitoring over 3 months as assessed using the e-monitor, and Pharm-CAT was associated with better adherence than e-monitoring alone or usual care as assessed by pill counts.^57^ Table 7 provides more detail.

### 1b What are the effects of medication adherence interventions on long-acting injectable (depot) psychopharmacological adherence?

Two studies (both moderate ROB) examined interventions targeting people along the psychotic spectrum using long-acting injectable (depot) antipsychotics, and both reported improved adherence.^61,62^ The first study was an RCT of outpatients prescribed depot antipsychotics receiving an intervention that included psychoeducation, early warning sign detection, and family education. Results indicated better adherence for the intervention group versus usual care at both the end of the intervention phase (12 months) and at 24-months follow-up.^61^ The second study was a prospective cohort study of homeless outpatients in a community setting receiving depot plus CAE, a manualized individual multicomponent behavioral intervention consisting of 4 modules (psychoeducation, substance use/modified Motivational Enhancement Therapy [MET], provider communication, medication management).^62^ CAE is customized based on an assessment at baseline to identify each patient's adherence vulnerabilities and reasons for non-adherence, with one to 4 of the modules assigned based on the results of the assessment. Results indicated significantly improved adherence through 25 weeks. Table 8 provides more detail.

### 1c What are the effects of medication adherence interventions on non-psychopharmacological adherence?

One RCT (moderate ROB) examined the effect of an intervention for medication adherence on non-psychopharmacological adherence in patients along the psychotic spectrum.^54^ The intervention was a technology intervention comparing telephone and SMS to telephone or SMS alone. There was no significant difference between groups. Table 9 provides study detail.

### 1d What are the effects of these interventions on patient outcomes?

Twenty included studies examined a wide range of patient outcomes, including symptom severity, quality of life, functional impairment, insight, time to first readmission/hospitalization, time spent in the hospital, and time to relapse. Patient outcome scales are described in Appendix F.

#### Symptom Severity

Seventeen studies examined the effect of interventions for medication adherence on positive (eg, delusions, hallucinations, disorganized speech or behavior), negative (eg, reduced emotional responsiveness, speech, movement, socialization, motivation), or total symptom severity in patients along the psychotic spectrum.

##### Positive Symptoms

Four studies evaluated positive symptoms using PANSS or CGI. Interventions included MI,^58^ a multicomponent behavioral intervention,^44^ an intervention involving family,^52^ and SMS reminders.^56^ Only the family intervention resulted in a significant decrease in positive symptoms.^52^ See Table 10 for more detail.

##### Negative Symptoms

Four studies evaluated negative symptoms using the PANSS scale or CGI, and findings associated with the interventions were mixed. Interventions included MI,^58^ a multicomponent behavioral intervention,^44^ an intervention involving family,^52^ and SMS reminders.^56^

The group family intervention resulted in a significant decrease in negative symptoms as assessed by the PANSS at 12 months; however, there was no significant difference as assessed by the CGI negative symptom scale at 3 months. SMS reminder messages were associated with a greater degree of change at 3 months and a decrease in severity of negative symptoms at 6 months.^56^ No other interventions were associated with a decrease in negative symptoms. Table 10 provides more detail.

##### Overall Symptom Severity

Seventeen studies evaluated total symptom severity using the PANSS, CGI, or BPRS, with mixed findings associated with the intervention. Of the 10 studies reporting PANSS scores,^44,45,47-49,52,55,58,61,62^ four^48,52,55,62^ reported significantly fewer symptoms associated with the intervention, including depot plus a customized multicomponent behavioral intervention at 25 weeks,^62^ a group family intervention,^52^ Adherence Therapy at 12-weeks post-discharge,^48^ and e-monitoring and pill counts as compared with self-reported adherence. MI did not reduce symptom severity for the full sample; however, it was associated with greater general symptom score reductions in women.^58^

Nine studies assessed symptoms using the BPRS,^43,46,50,51,53,54,57,59,60,62^ with 2 reporting better scores associated with the intervention. The first study, a study of homeless outpatients included depot plus a customized multicomponent behavioral intervention and reported improved scores at 13 and 25 weeks.^62^ The second study compared family psychoeducation to usual care, with better BPRS scores for the intervention group at 12 and 24 months.^51^ The other 6 studies did not find a difference in BPRS scores between groups.

Three studies reported CGI scores,^55,59,62^ with e-monitoring^55^ (at 8 weeks) and depot plus a customized multicomponent behavioral intervention for homeless participants^62^ reporting better scores at 13 and 25 weeks. Table 10 reports study detail.

#### Quality of Life

Four studies^46,47,49,56^ evaluated the effect of the interventions on quality of life, with no improvements associated with Adherence Therapy,^46^ Compliance Therapy,^47,49^ or a system-level intervention.^49^ However, daily SMS reminders as compared with usual care resulted in better quality of life scores at the end of the intervention (3 months), but not at 6 months follow-up.^56^ Table 10 reports study detail.

#### Functional Impairment

Eleven studies evaluated functional impairment using the GAF, Global Assessment Scale (GAS), or the Social and Occupational Functioning Scale (SOFAS).^43,47-49,51,52,57,59-62^ The studies reported mixed findings, with some showing no effect and others a positive effect of medication adherence interventions on functional impairment. The 2 studies comparing interventions involving family members to usual care found the intervention group to be less impaired,^51,52^ as did one study of depot plus CAE.^62^ However, no improvement or group differences were found in studies examining Adherence Therapy,^48^ e-monitoring,^57^ a system-level intervention,^49^ and shared decision-making.^59^ Results of the 3 studies examining Compliance Therapy were mixed, with 2 studies reporting no effect of Compliance Therapy on functional impairment,^47,49^ and one study reporting improvement in functional impairment associated with Compliance Therapy as compared to routine management and supportive counseling for up to 18 months.^43^ Similar results were found for studies examining CAT and Pharm-CAT, with one study reporting no improvement over time and as compared to e-monitoring,^57^ and a second study reporting higher functioning for CAT versus Pharm-CAT and usual care.^60^ Higher functioning was associated with Pharm-CAT as compared to usual care at 3 and 6 months, with no difference thereafter. Table 10 reports study detail.

#### Time to First Readmission/Hospitalization

The 10 studies examining time to first readmission or hospitalization reported mixed findings associated with interventions to improve medication adherence. Three studies comparing interventions involving family members to usual care reported significantly fewer admissions or longer time to readmission/hospitalization associated with the family intervention.^50-52^ One study comparing a system-level intervention to Compliance Therapy found that over one year, the system-level intervention resulted in longer time to readmission.^49^ Two other studies examining Compliance Therapy^43,47^ found that the intervention had no effect on readmission/hospitalization, nor did MI,^58^ depot plus CAE,^62^ or shared decision making.^59^ Table 10 provides more detail.

#### Time Spent in the Hospital

Three studies examined whether the interventions aimed at improving medication adherence had any effect on time spent in the hospital. Neither Compliance Therapy^43^ nor a group multicomponent behavioral intervention^44^ was associated with shorter stays; however, a family intervention was associated with fewer days in the hospital after rehospitalization at 24 months.^51^ Table 10 provides study detail.

#### Time to Relapse

The 2 studies examining time to relapse reported better outcomes associated with the intervention, with longer time to relapse associated with a family intervention,^52^ as well as both CAT and Pharm-CAT as compared to usual care.^60^ Table 10 provides study detail.

#### Side Effects

One study compared a system-level intervention to Compliance Therapy and examined side effects (eg, psychic, neurological, autonomic) related to psychopharmacological interventions, and found fewer side effects associated with Compliance Therapy. Table 10 reports study detail.

### 1e What are the harms and costs related to these interventions?

Two studies evaluated costs related to interventions to improve medication adherence in patients along the psychotic spectrum.^42,57^ The first study compared the costs related to the frequency and duration of service contacts for Compliance Therapy as compared with routine management and supportive counseling.^1^ Results indicated no difference in costs between the 2 interventions, and a positive relationship between costs and adherence for both groups (ie, regardless of intervention, better adherence was related to more contact).^42^ The second study^2^ compared Pharm-CAT to e-monitoring and usual care, and found that the average costs of treatment per patients were higher (significance not reported) for participants in the Pharm-CAT group as compared to e-monitoring.^57^ Table 11 reports study detail.

No studies reported harms specific to an intervention.

## KEY QUESTION 2 ADULTS WITH BIPOLAR DISORDER

We identified 4 studies (all moderate ROB) meeting inclusion criteria for patients with Type I or Type II bipolar disorder.^41,67-69^ All 4 studies examined interventions that included psychoeducation. One study examined the addition of individual psychoeducation to psychotherapy,^68^ another examined group psychoeducation alone,^69^ and the third examined the Life Goals Program,^67^ which includes psychoeducation and individualized problem solving skills with a focus on self-management. The fourth study evaluated CAE, a customized behavioral multicomponent intervention in which participants were assigned to one to 4 modules (psychoeducation, substance use/modified MET, provider communication, medication management) based on an assessment at baseline.^41^

Two of the 4 studies were conducted in Iran (one in an outpatient hospital clinic and the other in private and university clinics), with the other 2 conducted in community mental health clinics in the US. Studies assessed adherence using the MARS, the DAI, pill counts, and other measures. Common patient outcomes reported were severity of depression, mania, and functional impairment, as assessed by the Hamilton Depression Rating Scale (HAM-D), the Young Mania Rating Scale (YMRS), and the GAF. Appendices E and F provide brief descriptions of adherence and patient outcome assessment tools.

### 2a What are the effects of medication adherence interventions on psychopharmacological adherence?

Four studies examined interventions designed for psychopharmacological adherence. Two studies conducted in Iran examined psychoeducation alone, with one study focusing on individual sessions,^68^ and the other focusing on a group intervention.^69^ The first study randomized participants to standard psychotherapy plus individual psychoeducation (intervention group) or standard psychotherapy alone (control group), both of which included 8 weekly sessions followed by monthly question and answer sessions by phone for a total of 18 months.^68^ The study evaluated the effect of the interventions on adherence using the MARS, and results indicated significantly better adherence in the intervention group at 6, 12, and 18 months (P = .008). Table 12 provides more detail.

Table 12 Bipolar Disorder: Medication Adherence Outcomes

Study; N per Group | Sample and Setting | Intervention Groups | Intervention Intensity | Measure; Baseline | First Follow-up | Additional Follow-ups
Psychoeducation (Individual)
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | MARS NR | 6 months: M G1: 7.93 G2: 4.70 | 12 months: M G1: 7.80 G2: 4.00
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | MARS NR | 6 months: M G1: 7.93 G2: 4.70 | 18 months: M G1: 7.91 G2: 3.73
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | MARS NR | Group Difference: P = .008
Psychoeducation (Group)
Bahredar, et al, 2014^69^ G1: 15 G2: 15 G3: 15 | Adults 18 to 50 with type I bipolar disorder experiencing euthymic mood. Private and university clinics in Iran | G1: Pharmacotherapy plus group psychoeducation about BD and medication. G2: Pharmacotherapy plus supportive psychotherapy (placebo) G3: Pharmacotherapy only | Nine 90-minute weekly group sessions. | MARS M(SD) G1 (N = 15): 6.27 (0.88) G2 (N = 15): 6.47 (0.52) G3 (N = 15): 6.53 (0.64) | 3 months: M(SD) G1 (N = 15): 8.33 (0.65) G2 (N = 15): 4.91 (0.54) G3 (N = 15): 5.08 (0.79) | 6 months: M(SD) G1 (N = 15): 7.92 (1.38) G2 (N = 15): 4.36 (0.67) G3 (N = 15): 4.33 (0.49)
Bahredar, et al, 2014^69^ G1: 15 G2: 15 G3: 15 | Adults 18 to 50 with type I bipolar disorder experiencing euthymic mood. Private and university clinics in Iran | G1: Pharmacotherapy plus group psychoeducation about BD and medication. G2: Pharmacotherapy plus supportive psychotherapy (placebo) G3: Pharmacotherapy only | Nine 90-minute weekly group sessions. | MARS M(SD) G1 (N = 15): 6.27 (0.88) G2 (N = 15): 6.47 (0.52) G3 (N = 15): 6.53 (0.64) | Group Difference: F(2,31) = 55.09, P = .0001
Other Multicomponent Behavioral Interventions
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder with >2 years since first BD episode. Community-based mental health | G1: Treatment as usual plus Life Goals Program (LGP), a manualized group psychotherapy program that includes education and individualized problem solving to promote illness self-management. G2: Treatment as usual (medication management by a psychiatrist, psychosocial therapy and counseling by mental health clinicians and access to social services or case management) | Six weekly group sessions | DAI M(SD) G1 (N = 73): 7.18 (2.42) G2 (N = 69): 7.52 (2.07) | 3 months: M(SD) G1 (N = 53): 8.06 (1.81) G2 (N = 56): 7.50 (2.22) | 6 months: M(SD) G1 (N = 45): 8.20 (1.75) G2 (N = 45): 7.51 (2.27)
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder with >2 years since first BD episode. Community-based mental health | | Six weekly group sessions | DAI M(SD) G1 (N = 73): 7.18 (2.42) G2 (N = 69): 7.52 (2.07) | 3 months: M(SD) G1 (N = 53): 8.06 (1.81) G2 (N = 56): 7.50 (2.22) | 12 months: M(SD) G1 (N = 34): 8.27 (1.90) G2 (N = 30): 7.93 (1.86)
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder with >2 years since first BD episode. Community-based mental health | | Six weekly group sessions | DAI M(SD) G1 (N = 73): 7.18 (2.42) G2 (N = 69): 7.52 (2.07) | Group Difference: P = NS Secondary analysis examining DAI by group session attendance found ES = .59 for those attending 4-6 sessions, ES = .16 for those attending 1-2 sessions, and ES = .07 for those never attending session.
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder with >2 years since first BD episode. Community-based mental health | | Six weekly group sessions | Self-reported treatment adherence behaviors M(SD) G1 (N = 84): 79.46 (32.04) G2 (N = 80): 82.19 (30.34) | 3 months: M(SD) G1 (N = 62): 83.87 (28.66) G2 (N = 61): 81.15 (32.49) | 6 months: M(SD) G1 (N = 51): 90.20 (22.40) G2 (N = 55): 77.27 (35.12)
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder with >2 years since first BD episode. Community-based mental health | | Six weekly group sessions | Self-reported treatment adherence behaviors M(SD) G1 (N = 84): 79.46 (32.04) G2 (N = 80): 82.19 (30.34) | 3 months: M(SD) G1 (N = 62): 83.87 (28.66) G2 (N = 61): 81.15 (32.49) | 12 months: M(SD) G1 (N = 41): 95.73 (11.04) G2 (N = 39): 81.08 (30.85)
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder with >2 years since first BD episode. Community-based mental health | | Six weekly group sessions | Group Difference: P = NS
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder with >2 years since first BD episode. Community-based mental health | | Six weekly group sessions | A mixed model repeated measures analysis found a trend (P = .56) that more time in any treatment predicted more positive attitudes towards medication
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | G1: Customized adherence enhancement (CAE) is a manualized individual behavioral intervention consisting of 4 modules (psychoeducation, substance use/modified MET, provider communication, medication management). CAE is customized based on an assessment at baseline, with one to 4 modules assigned. | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6 week period. | DAI M(SE), MDN G1: 6.5 (0.3), 7.0 | Six Weeks: M(SE), MDN G1: 7.5 (0.3), 8.0 | 3 Months: M(SE), MDN G1: 7.8 (0.4), 8.0 WSRT Z = 2.815, P = .005
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6 week period. | DAI M(SE), MDN G1: 6.5 (0.3), 7.0 | Six Weeks: M(SE), MDN G1: 7.5 (0.3), 8.0 | 6 Months: M(SD), MDN G1: 8.1 (0.4), 9.0 t(30) = 4.252, P<.001
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6 week period. | Morisky Scale M(SE), MDN G1: 3.0 (0.2), 3.0 | 6 Months: M(SE), MDN G1: 1.3 (0.3),1.0 WSRT Z = -3.923, P<.001
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6 week period. | TRQ M% (SE), MDN Previous Week: G1: 48.0 (4.8), 43.0 Previous Month: G1: 51.4 (4.1), 43.0 | 6 Weeks: M% (SE), MDN Previous Week: G1: 23.5 (5.1), 14.0 Previous Month: G1: 20.7 (4.2), 14.0 | 3 Months: M% (SE), MDN Previous Week: G1 (N = 33): 24.0 (6.4), 0 WSRT Z = -3.054, P = .002 Previous Month: G1 (N = 33): 21.4 (5.6), 0 WSRT Z = -3.753, P<.001
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6 week period. | TRQ M% (SE), MDN Previous Week: G1: 48.0 (4.8), 43.0 Previous Month: G1: 51.4 (4.1), 43.0 | 6 Weeks: M% (SE), MDN Previous Week: G1: 23.5 (5.1), 14.0 Previous Month: G1: 20.7 (4.2), 14.0 | 6 Months: M% (SE), MDN Previous Week: G1 (N = 28): 25.2 (6.8), 3.5 WSRT Z = -2.561, P = .01 Previous Month: G1 (N = 28): 21.3 (5.5), 7.0 WSRT Z = -3.679, P<.001
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6 week period. | Longitudinal mixed models for both the previous month and the previous week as dependent variables were fit. The fixed effect of time was statistically significant for TRQ adherence for both the previous month (P<.001) and previous week (P = .002), indicating improved adherence over time.
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6 week period. | Pill Counts M% (SE), MDN 57.6 (7.6), 47.0 | Six Weeks: M% (SE), MDN 58.8 (20.7), 72.0 | 3 Months: M% (SE), MDN 38.0 (19.2), 29.0
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6 week period. | Pill Counts M% (SE), MDN 57.6 (7.6), 47.0 | Six Weeks: M% (SE), MDN 58.8 (20.7), 72.0 | 6 Months: M% (SE), MDN 35.3 (9.9), 27.5
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6 week period. | Only one-third of participants provided pill bottles, with only 2 participants at baseline and 3-months, and one participant at baseline and 6-months.

Note. Studies were conducted in the US unless otherwise specified. Brief descriptions of medication adherence assessments are reported in Appendix E.

1 Only 75% of the intervention group and 81% of the control group participated in baseline plus one other assessment, and only 49% of the intervention group participated in most or all of the group sessions, with 37% never participating.

Abbreviations: CAE = Customized adherence enhancement; DAI = Drug Attitude Inventory; ES = Effect size; MARS = Medication Adherence Rating Scale; M = Mean; MDN = Median; SD = Standard deviation; SE = Standard error; TRQ = Tablet Routine Questionnaire; WSRT = Wilcoxon signed-rank test.

In the second study participants were allocated to one of 3 groups – group psychoeducation, supportive group psychotherapy (placebo), or medication only (control).^69^ The intervention group received weekly 90-minute sessions over a period of 9 weeks, with medication adherence assessed using the MARS at 3 and 6 months. Data from this study indicated better adherence in the intervention group as compared to both placebo and control (F(2, 31) = 55.09, P = .0001). Table 12 provides more detail.

The third study was an RCT evaluating the effect of the Life Goals Program,^70^ a manualized structured group psychotherapy program focused on psychoeducation and individual application of problem solving skills.^67^ Participants were randomized to either the Life Goals Program plus usual care (medication management, counseling, access to social services and case management), or usual care alone. The Life Goals Program consists of 2 phases. Phase I included 6 weekly group (6-8 members) sessions and targets issues related to medication adherence, with Phase II comprised of ongoing monthly group sessions focused on functional goal attainment. Participants were enrolled in Phase I, and encouraged to attend Phase II. Medication adherence was assessed at baseline and at 3, 6, and 12 months using the DAI, which assesses attitudes towards psychotropic medication, and has been shown to correlate significantly with validated measures of medication adherence.^1^ Participants were also asked to provide an estimate of their adherence to all psychopharmacological medications combined. Data from this study indicated no significant difference between groups. However, there was a large amount of missing data (only 75% of the intervention group and 81% of the control group participated in baseline plus one other assessment) and only 49% of the intervention group participated in most or all of the group sessions, with 37% never participating. The authors conducted a secondary analysis comparing those who had participated in 4 to 6 sessions, those participating in 1 to 2 sessions, and those never attending a group session. Results of the secondary analysis indicated a difference in the effect of the intervention between those participating in 4 to 6 sessions (effect size = .59), and those participating in 1-2 (effect size = .16), and no sessions (effect size = .07). Table 12 provides more detail.

The fourth study was a cohort study evaluating the effect of CAE delivered over 4 weekly, individual, 60-minute sessions and up to 2 follow-up telephone sessions over a 6-week period.^41^ The DAI, the Morisky Scale, the Tablet Routine Questionnaire (TRQ) for both the previous week and the previous month, and pill counts were used to assess medication adherence outcomes at 6 weeks, 3 months, and 6 months. Findings indicated better DAI scores at both 6 weeks (P = .005) and at 6 months (P = .001), and better treatment adherence according to the Morisky Scale at 6 months (P = .001). Table 12 provides more detail.

### 2b What are the effects of medication adherence interventions on long-acting injectable (depot) psychopharmacological adherence?

We identified no studies examining medication adherence interventions for long-acting injectable (depot) psychopharmacological adherence.

### 2c What are the effects of medication adherence interventions on non-psychopharmacological adherence?

We identified no studies examining medication adherence interventions for non-psychopharmacological adherence.

### 2d What are the effects of these interventions on patient outcomes?

The 4 studies meeting inclusion criteria for medication adherence outcomes in patients with bipolar disorder also reported data related to patient outcomes, including quality of life, depression, mania, functional impairment, global functioning/severity, positive and negative affective symptoms, and hospital readmissions. Appendix F provides a summary of the included patient outcome scales.

#### Quality of Life

One study, which evaluated the addition of 8 weekly individual psychoeducation sessions and short telephone contact for 18 months compared to standard psychotherapy, assessed quality of life using the World Health Organization Quality of Life instrument (WHOQOL-BREF) at baseline, 6, 12, and 18 months.^68^ The WHOQOL-BREF includes the domains of physical health, mental health, social health, and the environment, and results indicated that mean scores (all time points combined) for the intervention group were significantly higher than the comparison group along all of the domains, indicating better quality of life (P = .000). Table 13 provides more detail.

Table 13 Bipolar Disorder: Patient Outcomes

Study; N per Group | Sample and Setting | Intervention Groups | Intervention Intensity | Measure; Baseline | First Follow-up | Additional Follow-ups
Psychoeducation (Individual)
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | WHOQOL-BREF NR | Mean of Baseline + 6, 12, 18 months Physical Health: G1: 63.81 G2: 53.25 Mental Health: G1: 66.65 G2: 54.29 Social Health: G1: 74.07 G2: 51.68 Environment: G1: 65.05 G2: 48.93
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | WHOQOL-BREF NR | Group Difference: P = .000 (all domains)
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | Recurrence of depression (HAM-D >7) M G1: 4.24 G2: 5.22 | 6 months: M G1: 6.27 G2: 10.19 | 12 months: M G1: 6.04 G2: 11.19
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | Recurrence of depression (HAM-D >7) M G1: 4.24 G2: 5.22 | 6 months: M G1: 6.27 G2: 10.19 | 18 months: M G1: 5.78 G2: 11.19
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | Recurrence of depression (HAM-D >7) M G1: 4.24 G2: 5.22 | Group Difference: P = .000
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | Recurrence of mania (Bech Rafaelsen Mania Scale >9) M G1: 4.18 G2: 4.34 | 6 months: M G1: 4.64 G2: 8.83 | 12 months: M G1: 4.88 G2: 9.95
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | Recurrence of mania (Bech Rafaelsen Mania Scale >9) M G1: 4.18 G2: 4.34 | 6 months: M G1: 4.64 G2: 8.83 | 18 months: M G1: 4.08 G2: 7.29
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | Recurrence of mania (Bech Rafaelsen Mania Scale >9) M G1: 4.18 G2: 4.34 | Group Difference: P = .000
Javadpour et al, 2013^68^ G1: 54 G2: 54 | Adults 18-60 with a history of at least 2 episodes of relapse in the past 2 or 3 episodes in the last 5 years. Outpatient psychology clinic in a hospital in Iran | G1: Standard psychotherapy plus individual psychoeducation about bipolar disorder and medication, and a question and answer session by telephone. G2: Standard psychotherapy | Eight 50-minute face-to-face weekly sessions, followed by monthly 10-minute phone calls for 18 months. | Hospital readmission 0 | M over 18 months G1: 0.22 G2: 1.41 P = .000
Psychoeducation (Group)
Bahredar, et al, 2014^69^ G1: 15 G2: 15 G3: 15 | Adults 18 to 50 with type I bipolar disorder experiencing euthymic mood Private and University Clinics in Iran | G1: Pharmacotherapy plus group psychoeducation about BD and medication. G2: Pharmacotherapy plus supportive psychotherapy (placebo) G3: Pharmacotherapy only | Nine 90-minute weekly sessions. | GAF M(SD) G1 (N = 15): 56.6 (3.58) G2 (N = 15): 56.67 (4.5) G3 (N = 15): 56.27 (3.17) | 3 months: M(SD) G1 (N = 15): 64.83 (1.9) G2 (N = 15): 56.27 (3.6) G3 (N = 15): 55.25 (3.91) | 6 months: M(SD) G1 (N = 15): 64.17 (2.12) G2 (N = 15): 56.0 (4.36) G3 (N = 15): 54.17 (5.08)
Bahredar, et al, 2014^69^ G1: 15 G2: 15 G3: 15 | Adults 18 to 50 with type I bipolar disorder experiencing euthymic mood Private and University Clinics in Iran | G1: Pharmacotherapy plus group psychoeducation about BD and medication. G2: Pharmacotherapy plus supportive psychotherapy (placebo) G3: Pharmacotherapy only | Nine 90-minute weekly sessions. | GAF M(SD) G1 (N = 15): 56.6 (3.58) G2 (N = 15): 56.67 (4.5) G3 (N = 15): 56.27 (3.17) | Group Difference: F(2,31) = 90.93, P = .0001
Other Multicomponent
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder. Community-based mental health | G1: Treatment as usual plus Life Goals Program (LGP), a manualized group psychotherapy program that includes education and individualized problem-solving to promote illness and self-management. G2: Treatment as usual (medication management by a psychiatrist, psychosocial therapy and counseling by mental health clinicians and access to social services or case management) | Six weekly group sessions | HAM-D M(SD) G1 (N = 83): 19.98 (11.45) G2 (N = 80): 17.08 (10.99) | 3 months: M(SD) G1 (N = 63): 16.30 (9.68) G2 (N = 65): 15.85 (10.52) | 6 months: M(SD) G1 (N = 51): 16.35 (10.18 G2 (N = 55): 15.96 (12.47)
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder. Community-based mental health | | Six weekly group sessions | HAM-D M(SD) G1 (N = 83): 19.98 (11.45) G2 (N = 80): 17.08 (10.99) | 3 months: M(SD) G1 (N = 63): 16.30 (9.68) G2 (N = 65): 15.85 (10.52) | 12 month: M(SD) G1 (N = 41): 16.02 (11. 73) G2 (N = 39): 14.39 (10.87)
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder. Community-based mental health | | Six weekly group sessions | HAM-D M(SD) G1 (N = 83): 19.98 (11.45) G2 (N = 80): 17.08 (10.99) | Group Difference: P = NS
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder. Community-based mental health | | Six weekly group sessions | HAM-D M(SD) G1 (N = 83): 19.98 (11.45) G2 (N = 80): 17.08 (10.99) | A mixed model repeated measures analysis found a trend (P = .056) that higher baseline HAM-D scores predicted more negative attitudes towards medications over time regardless of intervention.
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder. Community-based mental health | | Six weekly group sessions | YMRS M(SD) G1 (N = 84): 7.30 (5.41) G2 (N = 80): 7.58 (5.44) | 3 months: M(SD) G1 (N = 63): 6.14 (4.85) G2 (N = 65): 8.02 (5.38) | 6 months: M(SD) G1 (N = 51): 6.78 (5.36) G2 (N = 55): 7.69 (6.26)
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder. Community-based mental health | | Six weekly group sessions | YMRS M(SD) G1 (N = 84): 7.30 (5.41) G2 (N = 80): 7.58 (5.44) | 3 months: M(SD) G1 (N = 63): 6.14 (4.85) G2 (N = 65): 8.02 (5.38) | 12 months: M(SD) G1 (N = 41): 5. 85 (4.74) G2 (N = 39): 7.15 (5.60
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder. Community-based mental health | | Six weekly group sessions | YMRS M(SD) G1 (N = 84): 7.30 (5.41) G2 (N = 80): 7.58 (5.44) | Group Difference: P = NS
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder. Community-based mental health | | Six weekly group sessions | GAS M(SD) G1 (N = 83): 56.53 (12.43) G2 (N = 78): 58.22 (N = 12.00) | 3 months: M(SD) G1 (N = 61): 60.10 (11.63) G2 (N = 61): 59.05 (12.44) | 6 months: M(SD) G1 (N = 46): 61.72 (12.76) G2 (N = 53): 62.19 (14.42)
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder. Community-based mental health | | Six weekly group sessions | GAS M(SD) G1 (N = 83): 56.53 (12.43) G2 (N = 78): 58.22 (N = 12.00) | 3 months: M(SD) G1 (N = 61): 60.10 (11.63) G2 (N = 61): 59.05 (12.44) | 12 months: G1 (N = 40): 63.70 (12.66) G2 (N = 39): 64.51 (15.90)
Sajatovic et al, 2009^67^ G1: 84 G2: 80 | Adults with Type I or Type II bipolar disorder. Community-based mental health | | Six weekly group sessions | GAS M(SD) G1 (N = 83): 56.53 (12.43) G2 (N = 78): 58.22 (N = 12.00) | Group Difference: P = NS
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | G1: Customized adherence enhancement (CAE) is a manualized individual behavioral intervention consisting of 4 modules (psychoeducation, substance use/modified MET, provider communication, medication management). CAE is customized based on an assessment at baseline, with one to 4 modules assigned. | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6-week period. | BPRS M(SE), MDN G1: 43.6 (1.8), 42.5 | 3 Months: M(SE), MDN G1: 37.3 (2.1), 36.0 WSRT Z = -2.931, P = .003 | 6 Months: M(SE), MDN G1: 36.1 (2.3), 36.0 WSRT Z = -3.267, P = .001
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6-week period. | CGI-BP M(SE), MDN G1: 4.4 (0.16), 4.0 | 3 Months: M(SE), MDN G1: 3.9 (0.21), 4.0 t(31) = -1.717, P = .096 | 6 Months: M(SE), MDN G1: 3.6 (0.24), 3.0 t(29) = -3.657, P = .001
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6-week period. | GAF M(SE), MDN G1: 51.6 (1.2), 51.0 | 3 Months: M(SE), MDN G1: 55.7 (1.3), 51.0 WSRT Z = 1.797, P = .072 | 6 Months: M(SE), MDN G1: 58.0 (1.7), 60.0 t(29) = 3.671, P = .001
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6-week period. | HAM-D M(SE), MDN G1: 17.8 (1.1), 18.5 | 3 Months: M(SE), MDN G1: 16.2 (1.2), 16.0 t(31) = -1.182, P = .246 | 6 Months: M(SE), MDN G1: 15.3 (1.6), 15.0 WSRT Z = -2.010, P = .044
Sajatovic et al, 2012^41^ G1: 43 | Adults with Type I or Type II bipolar disorder and poor adherence, with >2 years since first BD episode. Community-based mental health | | Four weekly, in-person, 60-minute sessions and up to 2 follow-up telephone sessions over a 6-week period. | YMRS M(SE), MDN G1: 14.2 (1.2), 14.0 | 3 Months: M(SE), MDN G1: 11.2 (1.4), 9.0 WSRT Z = -1.638, P = .101 | 6 Months: M(SE), MDN G1: 9.6 (1.0), 9.0 t(29) = -3.404, P = .002

Note. Studies were conducted in the US unless otherwise specified. Brief descriptions of patient outcome assessments are reported in Appendix F.

1 Only 75% of the intervention group and 81% of the control group participated in baseline plus one other assessment, and only 49% of the intervention group participated in most or all of the group sessions, with 37% never participating.

Abbreviations: BPRS = Brief Psychiatric Rating Scale; CAE = Customized adherence enhancement; CGI-BP = Clinical Global Impression – Bipolar scale; GAF = Global Assessment of Functioning; GAS = Global Assessment Scale; HAM-D = Hamilton Depression Rating Scale; MET = Motivational Enhancement Therapy; WSRT = Wilcoxon signed-rank test.

#### Depression

Three studies assessed depression using the HAM-D.^41,67,68^ Data from the first study, which assessed the addition of individual psychoeducation sessions in participants who had experienced at least 2 episodes of relapse in the past 2 years or had a history of 3 episodes in the past 5 years (intervention group baseline mean [M] = 4.24), found significantly lower scores in the intervention group at 6, 12, and 18 months (P = .000).^68^ The second study, which evaluated the CAE in bipolar participants with poor adherence, found that while there was no significant difference from baseline to 3 months (M[SE] = 16.2[1.2], P = .246), as compared to baseline, HAM-D scores were significantly lower at 6 months (M[SE] = 15.3[1.6], P = .044).^41^

The third study compared the Life Goals Program, a group psychotherapy program including psychoeducation and individualized problem-solving, to treatment as usual (intervention group baseline M[SD] = 19.98[11.45]), and found no significant differences at 3, 6, and 12 months.^67^ However, a mixed model repeated measures analysis found a trend (P = .056) indicating that higher baseline HAM-D scores predicted more negative attitudes towards medications over time regardless of intervention. In this study, only 49% of the intervention group participated in most or all of the group sessions, and 37% never attended a group session. See Table 13 for more detail.

#### Mania

Three included studies assessed mania.^41,67,68^ Using the Bech Rafaelsen Mania Scale, one study^68^ assessed the addition of individual psychoeducation versus standard psychotherapy versus standard psychotherapy alone and found significantly lower mean mania scores at 6, 12, and 18 months (P = .000). Similar to findings for depression, another study^41^ found that while CAE resulted in no significant differences from baseline to 3 months (P = .101) on the YMRS, mania scores were significantly lower at 6 months (M[SE] = 9.6[1.0]) as compared with baseline (M[SE] = 14.2[1.2], P = .002). Also similar to findings for depression outcomes, a study^67^ comparing the Life Goals Program group to participants receiving usual care found no difference in YMRS scores. Table 13 provides more detail.

#### Functional Impairment

Three included studies examined outcomes related to functional impairment, 2 of which used the GAF,^41,69^ with one utilizing the predecessor to the GAF, the GAS.^67^ One study compared group psychoeducation to a placebo group receiving supportive psychotherapy, and to a control group composed of participants experiencing euthymic mood.^69^ GAF scores for all 3 groups were similar at baseline. Findings indicated that while there was no difference between the placebo and control groups, GAF scores for the intervention group were significantly higher than both placebo and control at 3 and 6 months (P = .0001), indicating higher levels of functioning.

Similar to other patient outcomes associated with CAE, there was no significant difference in functional impairment between baseline (M[SE] = 51.6[1.2]) and 3 months (M[SE] = 55.7[1.3], P = .072), but a significant improvement was observed from baseline to 6 months follow-up (M[SE] = 58.0[1.7], P = .001).^41^ Similarly, there was no difference between the Life Goals Program group and usual care at 3, 6, and 12 months.^67^ See Table 13 for more detail.

#### Global Functioning/Severity – Bipolar Disorder

One study examined the severity of depressive and manic episodes and the degree of change from the immediately preceding phase and from the worst phase of illness using the Clinical Global Impression scale for use in bipolar illness (CGI-BP), and found that CAE resulted no improvement between baseline (M[SE] = 4.4[.16]) and 3 months (M[SE] = 3.9[.21], P = .072), with significant improvement from baseline to 6-months follow-up (M[SE] = 3.6[.24], P = .001).^41^ See Table 13 for more detail.

#### Positive and Negative Affective Symptoms

One study assessed positive and negative affective symptoms using the BPRS.^41^ Unlike other patient outcomes associated with CAE, there was significant improvement from baseline (M[SE] = 43.6[1.8]) to both 3-months (M[SE] = 37.3[2.1], P = .003) and 6-months follow-up (M[SE] = 36.1[2.3], P = .001). Table 13 provides more detail.

#### Hospital Readmissions

One study examined hospital records to evaluate whether individual psychoeducation in addition to standard psychotherapy was associated with fewer hospital readmissions. Data indicated that over the 18-month study period, fewer participants in the intervention group were readmitted to the hospital as compared with participants receiving standard psychotherapy alone (.22% versus 1.41%, P = .000). See Table 13 for more detail.

### 2e What are the harms and costs related to these interventions?

We identified no studies addressing the harms or costs of interventions for medication adherence in patients with bipolar disorder.

## KEY QUESTION 3 ADULTS WITH PTSD

We identified no studies examining medication adherence interventions for patients with PTSD.

1 Healey et al (1998)^42^ found significantly better adherence associated with CT.

2 Velligan et al (2008)^60^ found no difference in adherence when comparing pharm-CAT to e-monitoring, with both groups significantly more adherent than usual care.