# REFERENCES

1 Nguyen TM, La Caze A, Cottrell N. (2014). What are validated self-report adherence scales really measuring?: a systematic review. Br J Clin Pharmacol.
2 Encinosa W, Bernard D, Dor A. (2010). Does prescription drug adherence reduce hospitalizations and costs? The case of diabetes. Adv Health Econ Health Serv Res.
3 Novick D, Haro JM, Suarez D, Perez V, Dittmann RW, Haddad PM. (2010). Predictors and clinical consequences of non-adherence with antipsychotic medication in the outpatient treatment of schizophrenia. Psychiatry Res.
4 Olfson M, Mechanic D, Hansell S, Boyer CA, Walkup J, Weiden PJ. (2000). Predicting medication noncompliance after hospital discharge among patients with schizophrenia. Psychiatr Serv.
5 Lang K, Meyers JL, Korn JR, et al. (2010). Medication adherence and hospitalization among patients with schizophrenia treated with antipsychotics. Psychiatr Serv.
6 Dilla T, Ciudad A, Alvarez M. (2013). Systematic review of the economic aspects of nonadherence to antipsychotic medication in patients with schizophrenia. Patient Prefer Adherence.
7 Sun SX, Liu GG, Christensen DB, Fu AZ. (2007). Review and analysis of hospitalization costs associated with antipsychotic nonadherence in the treatment of schizophrenia in the United States. Current Medical Research and Opinion.
8 Ho PM, Rumsfeld JS, Masoudi FA, et al. (2006). Effect of medication nonadherence on hospitalization and mortality among patients with diabetes mellitus. Arch Intern Med.
9 Cullen BA, McGinty EE, Zhang Y, et al. (2013). Guideline-concordant antipsychotic use and mortality in schizophrenia. Schizophr Bull.
10 Lehman AF, Lieberman JA, Dixon LB, et al. (2004). Practice guideline for the treatment of patients with schizophrenia, second edition. Am J Psychiatry.
11 Lieberman JA, Stroup TS, McEvoy JP, et al. (2005). Effectiveness of antipsychotic drugs in patients with chronic schizophrenia. N Engl J Med.
12 Moritz S, Peters MJ, Karow A, Deljkovic A, Tonn P, Naber D. (2009). Cure or curse? Ambivalent attitudes towards neuroleptic medication in schizophrenia and non-schizophrenia patients. Ment.
13 Diaz E, Levine HB, Sullivan MC, et al. (2001). Use of the Medication Event Monitoring System to estimate medication compliance in patients with schizophrenia. J Psychiatry Neurosci.
14 Valenstein M, Blow FC, Copeland LA, et al. (2004). Poor Antipsychotic Adherence Among Patients With Schizophrenia: Medication and Patient Factors. Schizophr Bull.
15 Sendt K-V, Tracy DK, Bhattacharyya S. (2015). A systematic review of factors influencing adherence to antipsychotic medication in schizophrenia-spectrum disorders. Psychiatry Res.
16 Velligan DI, Weiden PJ, Sajatovic M, et al. (2009). The Expert Consensus Guideline Series: Adherence problems in patients with serious and persistent mental illness. J Clin Psychiatry.
17 Dolder CR, Lacro JP, Jeste DV. (2003). Adherence to antipsychotic and nonpsychiatric medications in middle-aged and older patients with psychotic disorders. Psychosom Med.
18 Kreyenbuhl J, Dixon LB, McCarthy JF, Soliman S, Ignacio RV, Valenstein M. (2010). Does adherence to medications for type 2 diabetes differ between individuals with vs without schizophrenia?. Schizophr Bull.
19 Connolly KR, Thase ME. (2011). The clinical management of bipolar disorder: a review of evidence-based guidelines. Prim Care Companion CNS Disord.
20 Osterberg L, Blaschke T. (2005). Adherence to medication. N Engl J Med.
21 Scott J, Pope M. (2002). Nonadherence with mood stabilizers: Prevalence and predictors. J Clin Psychiatry.
22 Vieta E, Azorin J-M, Bauer M, et al. (2012). Psychiatrists' perceptions of potential reasons for non- and partial adherence to medication: Results of a survey in bipolar disorder from eight European countries. J Affect Disord.
23 Sajatovic M, Valenstein M, Blow FC, Ganoczy D, Ignacio RV. (2006). Treatment adherence with antipsychotic medications in bipolar disorder. Bipolar Disord.
24 Benedek DM, Friedman M, Zatzick DF, Ursano RJ. (2009). Guideline Watch (March 2009): Practice guideline for the treatment of patients with acute stress disorder and posttraumatic stress disorder. APA Practice Guidelines.
25 Kolandaivelu K, Leiden BB, O'Gara PT, Bhatt DL. (2014). Non-adherence to cardiovascular medications. Eur Heart J.
26 Zen AL, Whooley MA, Zhao S, Cohen BE. (2012). Post-traumatic stress disorder is associated with poor health behaviors: Findings from the Heart and Soul Study. Health Psychol.
27 Kronish IM, Edmondson D, Li Y, Cohen BE. (2012). Post-traumatic stress disorder and medication adherence: Results from the Mind Your Heart Study. J Psychiatr Res.
28 Velligan DI, Wang M, Diamond P, et al. (2007). Relationships among subjective and objective measures of adherence to oral antipsychotic medications. Psychiatr Serv.
29 Cassidy CM, Rabinovitch M, Schmitz N, Joober R, Malla A. (2010). A comparison study of multiple measures of adherence to antipsychotic medication in first-episode psychosis. J Clin Psychopharmacol.
30 Poulos C, Bae JP, Candrilli SD, Hauber AB. (2013). Quantifying Medication Adherence: Practical Challenges and an Approach to Linking Alternative Measures.
31 Viswanathan M, Golin CE, Jones CD, et al. (2012). Closing the quality gap: revisiting the state of the science (vol. 4: medication adherence interventions: comparative effectiveness). Evid rep/technol assess.
32 Relevo R, Paynter R. (2012). Peer review of search strategies.
33 Sampson M, McGowan J, Lefebvre C, Moher D, Grimshaw J. (2008). PRESS: Peer Review of Electronic Search Strategies.
34 Wallace BC, Small K, Brodley CE, Lau J, Trikalinos TA. (2012). Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the 2nd ACM SIGHIT International Health Informatics Symposium (IHI).
35 Brown University Evidence-based Practice Center (EPC). Systematic Review Data Repository.
36 Viswanathan M, Ansari M, Berkman N, et al. (2012). Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions.
37 Viswanathan M, Berkman N, Dryden D, Hartling L. (2012). Assessing Risk of Bias and Confounding in Observational Studies of Interventions or Exposures: Further Development of the RTI Item Bank.
38 Berkman N, Lohr K, Ansari M, et al. (2013). Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update.
39 Atkins D, Chang S, Gartlehner G, et al. (2011). Assessing the Applicability of Studies When Comparing Medical Interventions.
40 Sajatovic M. (2014). Customized Medication Adherence Enhancement for Adults With Bipolar Disorder (UH CAE). ClinicalTrialsgov.
41 Sajatovic M, Levin J, Tatsuoka C, et al. (2012). Six-month outcomes of customized adherence enhancement (CAE) therapy in bipolar disorder. Bipolar Disord.
42 Healey A, Knapp M, Astin J, et al. (1998). Cost-effectiveness evaluation of compliance therapy for people with psychosis. The British Journal of Psychiatry.
43 Kemp R, Kirov G, Everitt B, Hayward P, David A. (1998). Randomised controlled trial of compliance therapy: 18-month follow-up. The British Journal of Psychiatry.
44 Bechdolf A, Kohn D, Knost B, Pukrop R, Klosterkotter J. (2005). A randomized comparison of group cognitive-behavioural therapy and group psychoeducation in acute patients with schizophrenia: Outcome at 24 months. Acta Psychiatr Scand.
45 Byerly MJ, Fisher R, Carmody T, Rush A. (2005). A Trial of Compliance Therapy in Outpatients With Schizophrenia or Schizoaffective Disorder. J Clin Psychiatry.
46 Gray R, Leese M, Bindman J, et al. (2006). Adherence therapy for people with schizophrenia. European multicentre randomised controlled trial. Br J Psychiatry.
47 O'Donnell C, Donohoe G, Sharkey L, et al. (2003). Compliance therapy: a randomised controlled trial in schizophrenia. BMJ: British Medical Journal.
48 Schulz M, Gray R, Spiekermann A, Abderhalden C, Behrens J, Driessen M. (2013). Adherence therapy following an acute episode of schizophrenia: A multi-centre randomised controlled trial. Schizophr Res.
49 Skarsholm H, Stoevring H, Nielsen B. (2014). Effect of a system-oriented intervention on compliance problems in schizophrenia: a pragmatic controlled trial. schizophr.
50 Kopelowicz A, Zarate R, Wallace CJ, Liberman RP, Lopez SR, Mintz J. (2012). The ability of multifamily groups to improve treatment adherence in Mexican Americans with schizophrenia. Arch Gen Psychiatry.
51 Pitschel-Walz G, Bauml J, Bender W, Engel RR, Wagner M, Kissling W. (2006). Psychoeducation and Compliance in the Treatment of Schizophrenia: Results of the Munich Psychosis Information Project Study. J Clin Psychiatry.
52 Valencia M, Rascon ML, Juarez F, Escamilla R, Saracco R, Liberman RP. (2010). Application in Mexico of psychosocial rehabilitation with schizophrenia patients. Psychiatry: Interpersonal and Biological Processes.
53 Kavanagh K, Duncan-McConnell D, Greenwood K, Trivedi P, Wykes T. (2003). Educating acute inpatients about their medication: is it worth it? An exploratory study of group education for patients on a psychiatric intensive care unit. J Ment Health.
54 Beebe L, Smith KD, Phillips C. (2014). A comparison of telephone and texting interventions for persons with schizophrenia spectrum disorders. Issues Ment Health Nurs.
55 Frangou S, Sachpazidis I, Stassinakis A, Sakas G. (2005). Telemonitoring of Medication Adherence in Patients with Schizophrenia. Telemedicine and e-Health.
56 Montes JM, Medina E, Gomez-Beneyto M, Maurino J. (2012). A short message service (SMS)-based strategy for enhancing adherence to antipsychotic medication in schizophrenia. Psychiatry Res.
57 Velligan D, Mintz J, Maples N, et al. (2013). A randomized trial comparing in person and electronic interventions for improving adherence to oral medications in schizophrenia. Schizophr Bull.
58 Barkhof E, Meijer CJ, de Sonneville LM, Linszen DH, de Haan L. (2013). The effect of motivational interviewing on medication adherence and hospitalization rates in nonadherent patients with multi-episode schizophrenia. Schizophr Bull.
59 Hamann J, Cohen R, Leucht S, Busch R, Kissling W. (2007). Shared decision making and long-term outcome in schizophrenia treatment. J Clin Psychiatry.
60 Velligan DI, Diamond PM, Mintz J, et al. (2008). The use of individually tailored environmental supports to improve medication adherence and outcomes in schizophrenia. Schizophr Bull.
61 Lee S-H, Choi TK, Suh S, et al. (2010). Effectiveness of a psychosocial intervention for relapse prevention in patients with schizophrenia receiving risperidone via long-acting injection. Psychiatry Res.
62 Sajatovic M, Levin J, Ramirez LF, et al. (2013). Prospective trial of customized adherence enhancement plus long-acting injectable antipsychotic medication in homeless or recently homeless individuals with schizophrenia or schizoaffective disorder. J Clin Psychiatry.
63 Hayward P, Chan N, Kemp R, Youle S. (1995). Medication self-management: A preliminary report on an intervention to improve medication compliance. J Ment Health.
64 Kemp R, Hayward P, David A. (1997). Compliance therapy manual.
65 Gray R. Adherence therapy: Working together to improve health. A treatment manual for healthcare workers.
66 Dixon LB, Lehman AF. (1995). Family interventions for schizophrenia. Schizophr Bull.
67 Sajatovic M, Davies MA, Ganocy SJ, et al. (2009). A comparison of the life goals program and treatment as usual for individuals with bipolar disorder. Psychiatr Serv.
68 Javadpour A, Hedayati A, Dehbozorgi G-R, Azizi A. (2013). The impact of a simple individual psycho-education program on quality of life, rate of relapse and medication adherence in bipolar disorder patients. Asian J Psychiatr.
69 Bahredar MJ, Asgharnejad Farid AA, Ghanizadeh A, Birashk B. (2014). The efficacy of psycho-educational group program on medication adherence and global functioning of patients with bipolar disorder type I. International Journal of Community Based Nursing & Midwifery.
70 Bauer MS, McBride L. (2003). Structured group psychotherapy for bipolar disorder: The Life Goals Program.