# METHODS

## TOPIC DEVELOPMENT

This topic was submitted to the ESP Coordinating Center by Anthony Morreale, PharmD, MBA, BCPS, FASHP, Assistant Chief Consultant for Clinical Pharmacy Services and Health Services Research, in the VA Office of Pharmacy Benefits Management Services. We further refined the scope and key questions for this topic through a preliminary search of peer-reviewed literature, and in concert with internal partners and investigators, Dr. Morreale, and a Technical Expert Panel comprised of both VA and non-VA experts (Appendix A). The key questions for the review are as follows:

KQ1. In adults with psychotic spectrum disorders:

a. What are the effects of medication adherence interventions on psychopharmacological adherence?
b. What are the effects of medication adherence interventions on long-acting injectable (depot) psychopharmacological adherence?
c. What are the effects of medication adherence interventions on non-psychopharmacological adherence?
d. What are the effects of these interventions on patient outcomes?
e. What are the harms and costs related to these interventions?

KQ2. In adults with bipolar disorder:

a. What are the effects of medication adherence interventions on psychopharmacological adherence?
b. What are the effects of medication adherence interventions on long-acting injectable (depot) psychopharmacological adherence?
c. What are the effects of medication adherence interventions on non-psychopharmacological adherence?
d. What are the effects of these interventions on patient outcomes?
e. What are the harms and costs related to these interventions?

KQ3. In adults with posttraumatic stress disorder (PTSD):

a. What are the effects of medication adherence interventions on psychopharmacological adherence?
b. What are the effects of medication adherence interventions on non-psychopharmacological adherence?
c. What are the effects of these interventions on patient outcomes?
d. What are the harms and costs related to these interventions?

Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic Framework: Interventions for Medication Adherence in Adults with Psychotic Spectrum Disorders, Bipolar Disorder, and Posttraumatic Stress Disorder

Abbreviations: HbA1c = Glycated hemoglobin; PTSD = Posttraumatic Stress Disorder.

## SEARCH STRATEGY

A search strategy was developed in consultation with a research librarian, and was peer reviewed by a second research librarian using the instrument for Peer Review of Search Strategies (PRESS). ^32,33^ We conducted a primary review of the literature by systematically searching, reviewing, and analyzing the scientific evidence as it pertains to the key questions from database inception to January 27, 2015. To identify relevant articles, we searched MEDLINE®, PubMed, PsycINFO©, Embase®, CINAHL©, and the Cochrane Library (Ovid EBM Reviews: Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects, Health Technology Assessment, and NHS Economic Evaluation Database). In addition, we evaluated the bibliographies of included primary studies and any relevant systematic or nonsystematic reviews that were identified. To identify studies not published in peer-reviewed journals, we searched ClinicalTrials.gov, the World Health Organization's International Clinical Trials Registry Platform (ICTRP), ISRCTN Registry, Conference Papers Index, and Dissertations & Theses Global. The complete search strategy is provided in Appendix B.

## STUDY SELECTION

Criteria for population, interventions, comparators, outcomes, timing, and setting (PICOTS) were developed in collaboration with our stakeholders and Technical Expert Panel, and are provided in Table 3. We included only studies with adult populations examining interventions designed to improve medication adherence in general mental health settings (both inpatient and outpatient) that reported both a patient outcome measure and an objective or validated subjective measure of adherence.^1^ Studies set in forensic settings with incarcerated participants were excluded due to limited applicability (eg, including increased supervision, medication distribution). Eligible study designs included randomized controlled trials (RCTs) or methodologically rigorous observational studies, including before/after studies with at least 3 time points and that completed analyses that controlled for time. Using pre-specified inclusion/exclusion criteria (Appendix C), 2 independent reviewers reviewed titles and abstracts using Abstrackr^34^ and agreed on a final inclusion/exclusion decision for 10% of the search yield, with the remaining 90% decided by a single reviewer. Clinical trials were reviewed for inclusion according to the same pre-specified inclusion criteria by the primary investigator. At the full-text screening stage, 2 independent reviewers assessed all articles for inclusion (Appendix D). Discordant results were resolved through discussion or consultation with a third if discrepancies could not be resolved between the first 2 reviewers. Articles meeting eligibility criteria were included for data abstraction.

Table 3 PICOTS by Key Question

Key Question | KQ1. In patients with psychotic spectrum disorders:; a. What are the effects of medication adherence interventions on psychopharmacological adherence?; b. What are the effects of medication adherence interventions on [underlined: long-acting injectable (depot)] psychopharmacological adherence?; c. What are the effects of medication adherence interventions on non-psychopharmacological adherence?; d. What are the effects of these interventions on patient outcomes?; e. What are the harms and costs related to these interventions? | KQ2. In patients with bipolar disorder:; a. What are the effects of medication adherence interventions on psychopharmacological adherence?; b. What are the effects of medication adherence interventions on [underlined: long-acting injectable (depot)] psychopharmacological adherence?; c. What are the effects of medication adherence interventions on non-psychopharmacological adherence?; d. What are the effects of these interventions on patient outcomes?; e. What are the harms and costs related to these interventions? | KQ3. In patients with posttraumatic stress disorder (PTSD):; a. What are the effects of medication adherence interventions on psychopharmacological adherence?; b. What are the effects of medication adherence interventions on non-psychopharmacological adherence?; c. What are the effects of these interventions on patient outcomes?; d. What are the harms and costs related to these interventions?
Populations | Adults with psychotic spectrum disorders | Adults with bipolar disorder | Adults with PTSD
Intervention | Studies where the primary outcomes include medication adherence, including:; ▪ Patient-level interventions specifically designed to address medication adherence, such as: Compliance or Adherence Therapies, adherence skills training, psychosocial interventions (eg, psychoeducation, behavioral interventions, MI, cognitive interventions), customized adherence enhancement, family-supervised treatment, shared decision-making; or; ▪ Provider-level interventions specifically designed to address medication adherence, such as provider education, and training in MI; or; ▪ Systems-level interventions specifically designed to address medication adherence, such as: financial incentives, information and communication technology (eg, follow-up by phone, electronic reminder systems), reduction of economic barriers to adherence (eg, reducing copayments or prescription cost, cost-sharing), blister or unit-dose packaging, augmented pharmacy services, internet-based or eHealth interventions, simplified dosing or dosing frequency strategies, long-acting injectables (depot), case management or care coordination (eg, assertive community treatment, nurse-facilitated enhanced-treatment)
Comparator | - Other active interventions; - No treatment; - Usual care; - Studies with no comparison group only if outcome data are provided for baseline and at least 2 additional time points
Outcomes | Medication adherence:; ▪ Measured objectively (eg, medication container with electronic monitoring [eg, MEMS], pill counts, biological markers, observed intake, medication possession ratio, medication plasma level, electronic ingestible event marker); ▪ Measured subjectively by a validated patient self-report scale or measure (eg, Morisky Medication Adherence Scales [MMAS-8, MMAS-4 or MAQ]). See Nguyen et al for a list of validated measures.^1^; Patient outcomes:; ▪ Intermediate patient outcomes (HbA1c, blood pressure, lipids), clinical outcomes (mortality, morbidity), quality of life, patient satisfaction, health care utilization, quality of care, hospitalization, suicide/attempts, institutionalization, functional status, other.; Costs Exclude: Medication adherence not the primary outcome –OR– Patient self-report, caregiver report, case manager report, clinician's view based on therapeutic response, and other [underlined: non-validated subjective outcomes].
Timing | Short- and long-term outcomes
Study Design | RCTs; Methodologically rigorous observational studies (case control/cohort studies) that adjust for important confounders, and if no comparison group exists, data must be provided for baseline and at least 2 additional time points with analyses examining the trend and controlling for time.

## DATA ABSTRACTION

Data from published reports were abstracted into a customized Systematic Review Data Repository (SRDR)^35^ database by one investigator (among KK, DH, KJ, AM, AL) and confirmed by a second reviewer. From each study, we abstracted the following where available: study design, objectives, setting, population characteristics (including sex, age, race/ethnicity, diagnosis), subject eligibility and exclusion criteria, number of subjects, years of enrollment, duration of follow-up, the study and comparator interventions, important co-interventions, medication/class, number of medications, medication adherence outcomes, medication adherence thresholds, clinical outcomes, implementation factors, and harms.

## QUALITY ASSESSMENT

Two reviewers (among KK, DH, KJ, AM, AL, MM) independently assessed the quality of each study using the risk of bias (ROB) assessment criteria developed for a recent high-quality comparative effectiveness review examining medication adherence interventions that did not address the populations included in this report.^31^ This report followed the guidance and tools developed for the Agency for Healthcare Research and Quality's (AHRQ) Evidence-based Practice Centers (EPC), and allows for the assessment of ROB for a wide range of study designs.^36,37^ Disagreements were resolved through discussion with a third reviewer evaluating methodological quality if consensus could not be reached between the first 2 reviewers. Each study was given an overall summary assessment of low, medium, high, or unclear ROB (Appendices G & H):^36^

- Low ROB = We have confidence that the results represent the true treatment effect. The study reporting is adequate to judge that no major or minor sources of bias are likely to influence results.
- Medium ROB = We have some confidence that the results represent the true treatment effect. The study is susceptible to some bias, but the problems are not sufficient to invalidate the results.
- High ROB = We have low confidence that results represent the true treatment effect. The study has significant flaws that imply biases of various types that may invalidate its results; these may arise from serious errors in conduct, analysis, or reporting, large amounts of missing information, or discrepancies in reporting.
- Unclear ROB = The study is missing information, making it difficult to assess limitations and potential problems.

## DATA SYNTHESIS

We summarized the primary literature by abstracting relevant data and qualitatively synthesizing the literature for each key question/clinical population. Due the heterogeneity in the literature, a meta-analysis was not performed. We constructed evidence tables outlining study characteristics, organized by key question, and analyzed individual study findings to draw conclusions.

## RATING THE BODY OF EVIDENCE

We assessed the overall strength of evidence for outcomes using a method developed for AHRQ's EPCs.^38^ The AHRQ EPC method considers study limitations, directness, consistency, precision, and reporting bias to classify the strength of evidence for individual outcomes independently for randomized controlled trials and observational studies, with supplemental domains of dose-response association, plausible confounding that would decrease the observed effect, and strength of association, as well as separate guidance for applicability as follows:^39^

- High = We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable; in other words, another study would not change the conclusions.
- Moderate = We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
- Low = We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient = We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion