# INTRODUCTION

Non-adherence to medication is a serious problem in the United States (US). It is associated with increased emergency department visits and hospitalizations,^2-7^ higher costs of care,^2,6,7^ and greater mortality.^8,9^ For patients with serious mental illness, including schizophrenia and other psychotic spectrum disorders, bipolar disorder, and posttraumatic stress disorder (PTSD), adherence to psychopharmacological and/or non-psychopharmacological medications is an important concern. While some similarities exist, in general, these 3 populations are largely distinct in the factors associated with medication non-adherence and related outcomes, with some overlap in the interventions used to increase adherence.

For individuals with schizophrenia and other psychotic spectrum disorders, antipsychotic medications are a primary focus of treatment.^10^ Among people with schizophrenia, adherence to antipsychotic medication is estimated to be between roughly 25%^11,12^ to 50%^13^; in a study of patients with schizophrenia or schizoaffective disorder in the Veterans Affairs (VA) system, an adherence rate of 60% was reported.^14^ Wide variation exists in reported adherence rates, and largely depend on the length of time examined and the method used to measure adherence.^15^ Factors related to non-adherence in individuals with psychotic spectrum disorders may include patient-level factors such as lack of awareness or insight into the illness, negative attitudes towards medication,^15,16^ comorbid substance use, and cognitive impairment; demographic factors such as younger age, male gender, and lower socioeconomic status; relationship factors such as a poor therapeutic alliance and poor social support; and system-level factors such as co-pays, medication supervision, and access to mental healthcare providers.^16^ In addition to poor adherence to antipsychotic medications, individuals with schizophrenia and other psychotic spectrum disorders may be prone to poor adherence to medications prescribed for comorbid conditions, with one study reporting similar adherence rates for psychopharmacologic and non-psychopharmacologic therapies,^17^ and another study using VA data reporting a higher rate of non-adherence to oral hypoglycemic medications among Veterans with schizophrenia than without.^18^

Similar to individuals along the psychotic spectrum, psychopharmacological medications (eg, antipsychotics and mood stabilizers) are the first line of treatment for patients with bipolar disorder,^19^ with reported rates of adherence between 30%-57%.^20-22^ Studies conducted in VA settings reported an adherence rate of 51.9%.^16,23^ While many of the factors associated with non-adherence to antipsychotic medications – such as lack of insight into illness, comorbid substance use, cognitive function, and a poor therapeutic alliance – are similar to those found in individuals with psychotic spectrum disorders, other factors are more specific to patients with bipolar disorder, such as being unmarried, female, and homeless, having an external locus of control (eg, events are controlled by external factors rather than their own actions), having more suicide attempts, and receiving less-intensive psychopharmacologic treatments.^23^

Unlike patients with psychotic spectrum disorders or bipolar disorder, for individuals with PTSD, trauma processing therapy is often the first line of treatment.^24^ Pharmacologic treatment is also used to treat PTSD, including serotonergic antidepressants, adrenergic receptor antagonists such as prazosin, second-generation antipsychotics, and anticonvulsants. ^24^ For patients with PTSD, in addition to pharmacologic treatment for PTSD symptoms, non-adherence to medications for comorbid disorders may be a particular concern, with studies reporting higher rates of non-adherence to medications for cardiovascular disease.^25,26^ While few studies examine medication adherence rates in patients with PTSD, one study of individuals discharged from a VA PTSD treatment program reported that 66% were non-adherent during the 12 months following discharge. A second study of Veterans stated that 12% of participants reported not taking their medication, 41% reported forgetting to take their medication, and 24% reported skipping medication.^26,27^

Current measures of medication adherence vary widely, with a broad range of inherent limitations, often related to validity or cost. Objective measures of adherence include observed intake, pill counts, electronic monitoring (e-monitoring), administrative pharmacy claims, and blood plasma concentration levels; subjective measures include patient report, self-reported scales, patient diaries, reports by caregivers or case managers, and clinician's views on adherence based on therapeutic response.^28-30^

Due to the extensiveness of medication non-adherence and its severe health consequences for patients with severe mental illness, many interventions have been developed to try to combat this problem. Interventions for medication adherence include patient-level interventions such as Adherence and Compliance Therapies; adherence skills trainings; psychosocial and behavioral interventions, including cognitive behavioral therapy (CBT) and Motivational Interviewing (MI), shared decision-making, customized adherence enhancement (CAE), and interventions involving family members. Provider-level interventions include provider education and training in MI. System-level interventions include financial incentives; methods related to information and communication technology (eg, phone follow-up, electronic reminder systems, e-Health interventions, refill reminders); reducing economic barriers (eg, cost-sharing, reducing co-pays); blister or unit dose packaging; case management or care coordination; and simplified dosing or dosing frequency strategies, including long-acting injectables. A recent review of interventions for medication adherence in patients with chronic illness found that educational interventions and case management were consistent in improving adherence across different clinical conditions, as were clinical reminders, pharmacist-led multicomponent approaches, and reducing out of pocket expenses for patients.^31^ While this review did examine interventions for medication adherence in patients with depression, it did not include other serious mental illnesses.

The goal of this evidence report is to summarize the current evidence examining the effectiveness of interventions to improve medication adherence in patients with psychotic spectrum disorders, bipolar disorder, and PTSD, the effect of these interventions on patient outcomes, as well as the related costs and any associated intervention specific harms. As the Veterans Health Administration (VHA) continues to strive to provide high quality care, a better understanding of adherence interventions for these distinct populations will help to aid the VA in determining the programs and policies most appropriate for improving Veterans' health.