# APPENDIX I PEER REVIEW COMMENTS/AUTHOR RESPONSES

Question Text | Reviewer Number | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | 1 | Yes | Noted.
Are the objectives, scope, and methods for this review clearly described? | 3 | Yes | Noted.
Are the objectives, scope, and methods for this review clearly described? | 4 | Yes | Noted.
Are the objectives, scope, and methods for this review clearly described? | 5 | Yes | Noted.
Are the objectives, scope, and methods for this review clearly described? | 6 | Yes | Noted.
Is there any indication of bias in our synthesis of the evidence? | 1 | No | Noted.
Is there any indication of bias in our synthesis of the evidence? | 3 | No | Noted.
Is there any indication of bias in our synthesis of the evidence? | 4 | No | Noted.
Is there any indication of bias in our synthesis of the evidence? | 5 | No | Noted.
Is there any indication of bias in our synthesis of the evidence? | 6 | No | Noted.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 1 | No | Noted.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 3 | No | Noted.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 4 | No | Noted.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 5 | No | Noted.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 6 | No | Noted.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | On pg. 11, the last sentence (lines 12-18) is very long and somewhat difficult to read. Consider rewording. | Thank you, this section has been revised for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | On pg. 11 (lines 36-41) as it reads currently, it is assuming that the intervention group received more frequent interactions. Unless this can be quantified that the intervention group did indeed receive more frequent care interactions compared to usual care, consider removing or restating, especially the last sentence of the paragraph. | Thank you, this section has been revised for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | On pg. 89 there are two typos. Line 33 “will” should be “with”. Line 39 “is” should be inserted before “warranted”. | Thank you, these errors have been corrected.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | This evidence based synthesis addresses medication adherence in adults with psychotic spectrum disorders, bipolar disorder, and PTSD. The questions are clinically important. The method for addressing the question is standard. It is unfortunate that the authors did all of this work, only to find that the literature is so poor that few conclusions can be drawn about interventions for these populations. Nonetheless, knowing that more well-designed and –conducted studies are needed is an important finding for researchers and policymakers. Several suggestions for improving the readability of this report are detailed by section below. | Noted.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Executive summary Study selection: • please address design of studies that were included. Consider using PICOTS terminology; interventions and comparators are not described but should be. | Thank you, this section has been revised.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • It is difficult to understand the take-home message from each comparison due to the lack of clarity of writing. Each section describes the evidence in a confident manner, which is later undermined by “but the strength of evidence is poor.” It would be helpful to describe the strength of evidence first so that the reader can keep this in mind as reading the conclusions about the findings. | Thank you. Our summaries at the beginning of each section include a statement about the strength of evidence, and strength of evidence is detailed in subsequent tables (e.g., Table 14).
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • Wording of “Of the 518 clinical trials identified…” it is unclear how these are different from the 152 identified. This reviewer assumes that the 518 were identified from clinicaltrials.gov but is unsure. Please specify the source of each. | Thank you, we have revised this sentence for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • Unclear is the use of “controls.” Comparator might be a better term. There is heterogeneity in comparators, but the use of the word “controls” seems to imply that they are similar across studies. | Thank you. We have changed the term controls to comparators.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • Use of “Compliance Therapy” as a proper noun is confusing. Is this a standard behavioral approach? If so, what is it? | Thank you, we have revised this sentence for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • Unclear is the criterion for determining whether a study was considered significant. Is it effect size or type 2 error rate? | Thank you. Significance was determined according to the individual studies, and given the heterogeneity amongst studies and the qualitative nature of the review, we did not compute summary statistics. Tables in the main report (e.g., Table 4) provide data for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • Please do not use the phrase “trend” when something was nonsignificant. Many published studies are underpowered, so trend could be misleading. | Thank you. We have removed the term trend from the report text.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • System-level intervention definition is described as including e-monitoring, yet in the results, e-monitoring is listed under technology interventions. Here and in the larger report, the authors need to be clear by what e-health interventions are and whether they are patient or system-level. This reviewer tends to think of them as patient-level. | Thank you. We have revised this sentence for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • “Two RCTs examined e-monitoring…” Compared to what? | Thank you. E-monitoring was compared to a variety of comparators in both studies. We have added this language for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • Under technology interventions, the authors seem to be confusing outcome with intervention “One study reported both a significant…” | Thank you. We have revised this sentence for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • P.7 section d: what was the finding related to the four studies? | Thank you. We have revised this section for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Results: • P.8 section e: What is the effectiveness? It seems that an incremental cost effectiveness ratio is needed because the cost information alone is not helpful if comparing very different interventions. | Thank you, noted. As we conducted only a qualitative synthesis, we did not compute summary statistics not included in the original papers.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | - Table 1: system-level intervention: this needs to be defined, perhaps as a footnote. As mentioned earlier, it is unclear whether this includes e-monitoring, which is something that happens at the patient level. | Thank you. We have removed e-monitoring as an example of a system-level intervention.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | - Table 1: In this table, it would be helpful to have a column for comparator. | Thank you. Due to space considerations, we have added comparators to the findings column for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | - Table 1: SMS needs to be defined in the footnote. | Thank you, the definition for this abbreviation has been added.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Discussion: • A more extensive discussion of the types of comparator groups and the impact on conclusions is needed. | Thank you. We have revised this section for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Discussion: • Note that “medication” is often misspelled as “mediation” in this report. | Thank you, this has been corrected.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Full report Introduction: • The series of paragraphs are not joined by transitions, so it reads as a series of paragraphs instead of a coherent introduction. | Thank you. We have added subheadings to address.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Introduction: • There are so much data on adherence and factors associated with adherence that the authors do not build a strong case for the need for this review. If so much is already known, why is this review needed? | Thank you. This paragraph discusses the factors related to non-adherence, as well as what is known about adherence among people with psychotic spectrum disorders generally and in the VHA. The purpose of the review is to examine interventions potentially aimed at addressing these factors and increasing adherence.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Study selection: • Which criteria are used to determine whether a self-report measure is “validated?” There is mixed opinion, for example, as to whether the Morisky measure meets criteria for validity and reliability, and this is true of other measures. | Thank you. We used Nguyen, La Caz, and Cotrell (2014) as a basis of self-report measure/validity. We have added this reference to Table 3.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Study selection: • What is the difference between no treatment and usual care? Are these really different? This can be difficult to discern given that many authors do not define usual care. Usual care differs by site. Consider using the typology of control groups by Ken Freedland. http://www.ncbi.nlm.nih.gov/pubmed/21536837 | Thank you. And thank you for providing the article. For populations such as these, usual care (most often including treatment such as psychotherapy, contact with a psychiatrist to adjust medications, etc.) often differs from no treatment. Tables in the full report provide a description of the comparator.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Key Question 1: As in the executive summary, the meaning of “Adherence Therapy” and “Compliance Therapy” is not clear. Definitions are needed. Did the studies using these types of interventions always come from the same groups of authors? If not, then did different research groups use the terms in the same way? It is important to recognize that what authors say they are measuring or doing is not always what they are actually doing. It is up to the systematic reviewer to make sense of it and then convey that to the audience. | Thank you. This section has been revised for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Summary and discussion: As with the executive summary, there is tension between what the authors found and the risk of bias and strength of evidence. It is important to use precise wording to indicate why the evidence is poor or insufficient. It would be helpful to indicate primary reasons why, for example, the body of literature on (type of intervention in X population) is insufficient. Is it because the existing studies have high risk of bias, because there are too few studies, or other reasons? | Thank you. The reasons for strength of evidence ratings are outlined in the details sections associated with each type of intervention, and outlined in subsequent tables (e.g., Table 14).
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Limitations: The authors indicate that they used methodologically rigorous studies, but they included studies with high risk of bias, which seems to go against the statement that they only included rigorous studies. A more accurate statement would be that they included all studies (exclusion on the grounds of quality is an important limitation of some reviews) and then assessed risk of bias and used it to qualify their conclusions. | Thank you. We have revised this section for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Discussion: The conclusions about the status of PTSD literature are confusing. On the one hand, the authors assert that there is limited evidence that adherence is poor in this population. That would seem to indicate that perhaps there is no need to evaluate interventions. But the authors go on to say that future research is needed to evaluate interventions in this population. | Thank you. We have revised this section for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | This reviewer is left thinking that the studies are so poor that we simply cannot draw any conclusions about any medication adherence intervention in any of these populations. Is that the take-home message the authors want to convey? | Thank you. Yes, given the limited number of studies examining specific types of interventions/intervention components, and that the strength of evidence for all but family and technology interventions (both low) was insufficient, our conclusion is that the current state of the literature precludes strong conclusions and recommendations other than related to the need for future research.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | Very thorough. Clear how articles were identified and selected. ROB ratings and how they are made are clear. Some suggestions for improvement: | Thank you, noted.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | Seems incomplete without a frank discussion of methodological issues including sample bias (most patients entering RTC's for adherence are more adherent than most patients); | Thank you. This section has been revised to include this discussion.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | Plasma levels are not appropriate for assessing degree of adherence (most patients take some medication which will show up); | Thank you, noted. We found that the few included studies assessing plasma levels differentiated adherence by the amount of medication found; for example, the levels of medication found in the blood compared to levels that would be expected in a fully adherent patient.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | Many studies do not use objective measures (pill counts, electronic monitors) and should likely be weighted differently from those using objective measures of adherence. | Thank you. These factors were taken into consideration, along with others, in rating the strength of evidence.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | While I understand investigating whether LAI improves adherence, the focus of LAI therapy is not really on improving adherence it is on identifying when non-adherence occurs. Moreover, more than even studies of other methodologies, studies of LAI have incredibly high levels of sample bias that set them up to fail. | Thank you. We have added a statement to the discussion regarding this point.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | It would have been good at the beginning to outline an example of a body of literature which indicates sufficient evidence. Citing AHRQ guidelines I don't think is enough for the reader, especially since everything came out Insufficient. What would a body of evidence need to do to be sufficient? Are two positive studies enough where one is at least low ROI and neither are high ROB? Are 3 positive studies needed with all low ROB? Is standard treatment an adequate control? Do studies need the same active comparator to provide solid evidence or can an intervention use different active comparators in different studies and be considered a replication of the main finding? It is not clear how the authors took the data and made this final determination. | Thank you. There are numerous variables associated with strength of evidence, and the process is too complicated to outline in the body of this report. In this review, many of the interventions were evaluated by only one study, or there were inconsistent findings. For transparency, we provide details related to our rating in the comments sections of our tables (e.g., Table 1).
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | The report is well written and I believe it accurately reflects the literature on the key questions. The lack of literature limits interpretation which further limits reviewer comment. | Thank you, noted.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | Page 11, lines 38-41 and Page 88, lines 38-41: It may not be necessary to control for increased attention if is inherent from the intervention, i.e., cannot be separated. | Thank you, noted. We have revised this section slightly, and included this discussion to raise the possibility of a positive effect due to increased attention.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6 | I believe the review is comprehensive and well done. | Thank you, noted.