# APPENDIX H RISK OF BIAS: OBSERVATIONAL STUDIES

RISK OF BIAS: OBSERVATIONAL STUDIES, PART 1

Author, Year | Were providers blinded to intervention or exposure status of participants? | Participants blinded to intervention or exposure status? | Outcome assessors blinded to intervention or exposure status of participants? | Did strategy for recruiting participants into study differ across study groups? | Baseline characteristics similar between groups? If not, did analysis control for differences?
Byerly et al, 2005^45^ | Unclear | Unclear | Yes | No | Yes
Kavanagh et al, 2003^53^ | Unclear | Yes | Unclear | No | Unclear
Lee et al, 2010^61^ | Unclear | No | Yes | No | Yes
Sajatovic et al, 2012^41^ | NA | NA | NR | No | NA
Sajatovic et al, 2013^62^ | NA | NA | NA | No | NA
Skarsholm et al, 2014^49^ | No | No | No | No | Yes

RISK OF BIAS: OBSERVATIONAL STUDIES, PART 2

Author, Year | Impact from any concurrent intervention or unintended exposure that might bias results ruled out? | Did variation from study protocol compromise study conclusions? | High rate of differential or overall attrition? | Did attrition result in difference in group characteristics between baseline (or randomization) and follow-up? | Analysis conducted on an intention-to-treat (ITT) basis?
Byerly et al, 2005^45^ | Unclear | Unclear | NA | NA | Unclear
Kavanagh et al, 2003^53^ | NR | Unclear | No | NA | Unclear
Lee et al, 2010^61^ | Yes | NR | Yes | No | Yes
Sajatovic et al, 2012^41^ | No | NR | Yes | NA | NR
Sajatovic et al, 2013^62^ | Unclear | Unclear | Yes | No | Unclear
Skarsholm et al, 2014^49^ | Unclear | No | No | No | Yes

RISK OF BIAS: OBSERVATIONAL STUDIES, PART 3

Author, Year | Inclusion/exclusion criteria measured using valid and reliable measures, implemented consistently across all study participants? | Medication adherence outcomes assessed using valid and reliable measures, implemented consistently across all study participants? When adherence requires skills (eg, pill bottle, SMS), does the intervention measure or account for varied skill levels? | Do authors justify medication adherence thresholds? | Are health outcomes assessed using valid and reliable measures, implemented consistently across all study participants? | Harms assessed using valid and reliable measures, implemented consistently across all study participants?
Byerly et al, 2005^45^ | Yes | Yes | Yes | Yes | NR
Kavanagh et al, 2003^53^ | Yes | Yes | Yes | Yes | NR
Lee et al, 2010^61^ | Yes | Yes | Yes | Yes | NR
Sajatovic et al, 2012^41^ | Yes | Yes | No | Yes | NR
Sajatovic et al, 2013^62^ | Yes | Yes | Unclear | Yes | Yes
Skarsholm et al, 2014^49^ | Yes | Yes | Yes | Yes | Yes

RISK OF BIAS: OBSERVATIONAL STUDIES, PART 4

Author, Year | Potential outcomes pre-specified by researchers? Are all pre-specified outcomes reported? | Were incomplete outcome data adequately addressed? | Important confounding and modifying variables taken into account in the design and/or analysis? (eg, through matching, stratification, multivariable analysis, or other approaches?) | Additional Bias: Was the study apparently free of other problems that could put it at a high risk of bias? If no, please describe | Risk of Bias
Byerly et al, 2005^45^ | Yes | Unclear | Yes | Yes | High
Kavanagh et al, 2003^53^ | Yes | NR | Unclear | Unclear | High
Lee et al, 2010^61^ | Yes | NR | No | Yes | Moderate
Sajatovic et al, 2012^41^ | Yes | No | Unclear | Yes | Moderate
Sajatovic et al, 2013^62^ | Yes | Unclear | Yes | Yes | Moderate
Skarsholm et al, 2014^49^ | Yes | Yes | Yes | Yes | Moderate