# APPENDIX G RISK OF BIAS: TRIALS

RISK OF BIAS: TRIALS, PART 1

Author, Year | Method of randomization adequate? | Allocation of treatment adequately concealed? | Were providers blinded to intervention or exposure status of participants? | Participants blinded to intervention or exposure status? | Outcome assessors blinded to intervention or exposure status of participants?
Bahredar et al, 2014^69^ | NR | NR | NR | NR | NR
Barkhof et al, 2013^58^ | Yes | Yes | No | Yes | Yes
Bechdolf et al, 2005^44^ | Yes | Yes | Yes | Unclear | Yes
Beebe et al, 2014^54^ | Yes | Unclear | No | No | Yes
Frangou et al, 2005^55^ | Yes | No | No | No | No
Gray et al, 2006^46^ | Yes | Yes | Yes | No | Yes
Hamann et al, 2007^59^ | Unclear | Unclear | No | No | No
Healey et al, 1998^42^ | Yes | NR | NR | Unclear | NR
Javadpour et al, 2013^68^ | Yes | Yes | Unclear | Unclear | Yes
Kemp et al, 1998^43^ | Yes | NR | Unclear | Yes | Yes
Kopelowicz et al, 2012^50^ | Yes | Unclear | Unclear | No | Yes
Montes et al, 2012^56^ | Yes | Yes | No | No | No
O'Donnell et al, 2003^47^ | Yes | NR | Yes | NR | Yes
Pitschel-Walz et al, 2006^51^ | Yes | Yes | Yes | No | Yes
Sajatovic et al, 2009^67^ | NR | NR | No | No | No
Schulz et al, 2013^48^ | Yes | Yes | Yes | No | Yes
Valencia et al, 2010^52^ | No | No | Yes | No | Yes
Velligan et al, 2008^60^ | Unclear | Unclear | Unclear | No | Yes
Velligan et al, 2013^57^ | Yes | Yes | Unclear | Unclear | Yes

RISK OF BIAS: TRIALS, PART 2

Author, Year | Did strategy for recruiting participants into study differ across study groups? | Baseline characteristics similar between groups? If not, did analysis control for differences? | Impact from any concurrent intervention or unintended exposure that might bias results ruled out? | Did variation from study protocol compromise study conclusions? | High rate of differential or overall attrition?
Bahredar et al, 2014^69^ | NR | Unclear | NR | NR | No
Barkhof et al, 2013^58^ | No | Yes | Unclear | Unclear | No
Bechdolf et al, 2005^44^ | No | Yes | No | NR | Yes
Beebe et al, 2014^54^ | No | Yes | NR | NR | No
Frangou et al, 2005^55^ | No | Yes | Unclear | Unclear | No
Gray et al, 2006^46^ | No | Yes | Unclear | No | No
Hamann et al, 2007^59^ | Yes | Yes | NR | NR | No
Healey et al, 1998^42^ | Yes | Yes | Unclear | NR | Yes
Javadpour et al, 2013^68^ | Yes | Yes | Unclear | Yes | No
Kemp et al, 1998^43^ | No | Yes | No | NR | Yes
Kopelowicz et al, 2012^50^ | No | Yes | No | No | Yes
Montes et al, 2012^56^ | No | Yes | Unclear | No | No
O'Donnell et al, 2003^47^ | No | Yes | Yes | NR | No
Pitschel-Walz et al, 2006^51^ | No | Yes | Unclear | Unclear | No
Sajatovic et al, 2009^67^ | No | Yes | No | NR | Yes
Schulz et al, 2013^48^ | No | No | Yes | Unclear | Yes
Valencia et al, 2010^52^ | No | Yes | No | Unclear | Yes
Velligan et al, 2008^60^ | Yes | Yes | Unclear | Unclear | No
Velligan et al, 2013^57^ | No | Yes | Unclear | No | Yes

RISK OF BIAS: TRIALS, PART 3

Author, Year | Did attrition result in difference in group characteristics between baseline (or randomization) and follow-up? | Analysis conducted on an intention-to-treat (ITT) basis? | Inclusion/exclusion criteria measured using valid and reliable measures, implemented consistently across all study participants? | Medication adherence outcomes assessed using valid and reliable measures, implemented consistently across all study participants? When adherence requires skills (eg, pill bottle, SMS), does the intervention measure or account for varied skill levels? | Do authors justify medication adherence thresholds?
Bahredar et al, 2014^69^ | NR | Yes | Yes | Unclear | NA
Barkhof et al, 2013^58^ | No | No | Yes | Yes | NA
Bechdolf et al, 2005^44^ | No | Yes | Yes | Unclear | No
Beebe et al, 2014^54^ | NR | Unclear | Yes | Yes | Yes
Frangou et al, 2005^55^ | No | Yes | Yes | Yes | Yes
Gray et al, 2006^46^ | No | Yes | Yes | Yes | Yes
Hamann et al, 2007^59^ | No | Yes | Yes | Yes | Yes
Healey et al, 1998^42^ | Unclear | NR | Yes | NA | NA
Javadpour et al, 2013^68^ | No | Unclear | Yes | Yes | NR
Kemp et al, 1998^43^ | Unclear | Unclear | Yes | Yes | Yes
Kopelowicz et al, 2012^50^ | Unclear | Yes | Yes | Yes | Yes
Montes et al, 2012^56^ | No | Yes | Yes | Yes | Yes
O'Donnell et al, 2003^47^ | No | Yes | Yes | Yes | Yes
Pitschel-Walz et al, 2006^51^ | No | No | Yes | Yes | Yes
Sajatovic et al, 2009^67^ | Unclear | NR | Yes | Unclear | NA
Schulz et al, 2013^48^ | No | Yes | Yes | Yes | Yes
Valencia et al, 2010^52^ | No | Unclear | Yes | Unclear | Unclear
Velligan et al, 2008^60^ | No | No | Yes | Yes | No
Velligan et al, 2013^57^ | No | Unclear | Yes | Yes | Yes

RISK OF BIAS: TRIALS, PART 4

Author, Year | Are health outcomes assessed using valid and reliable measures, implemented consistently across all study participants? | Harms assessed using valid and reliable measures, implemented consistently across all study participants? | Potential outcomes pre-specified by researchers? Are all pre-specified outcomes reported? | Were incomplete outcome data adequately addressed? | Important confounding and modifying variables taken into account in the design and/or analysis? (eg, through matching, stratification, multivariable analysis, or other approaches?) | Additional Bias: Was the study apparently free of other problems that could put it at a high risk of bias? If no, please describe | Risk of Bias
Bahredar et al, 2014^69^ | Yes | NR | Yes | NR | Yes | Yes | Moderate
Barkhof et al, 2013^58^ | Yes | NR | Yes | Unclear | No | Yes | Low
Bechdolf et al, 2005^44^ | Yes | NR | Yes | Yes | Yes | Yes | Moderate
Beebe et al, 2014^54^ | Yes | NR | Yes | Unclear | Yes | Yes | Moderate
Frangou et al, 2005^55^ | Yes | NR | Yes | Unclear | Yes | Unclear | High
Gray et al, 2006^46^ | Yes | NR | Yes | Yes | Yes | Yes | Low
Hamann et al, 2007^59^ | Yes | NR | Yes | Yes | Unclear | Yes | High
Healey et al, 1998^42^ | Yes | NR | Unclear | Unclear | Yes | Yes | High
Javadpour et al, 2013^68^ | Yes | NR | Unclear | NR | Unclear | Yes | Moderate
Kemp et al, 1998^43^ | Yes | NR | Yes | No | NR | Yes | High
Kopelowicz et al, 2012^50^ | Yes | NR | Unclear | Unclear | No | Unclear | Moderate
Montes et al, 2012^56^ | Yes | NR | Yes | NR | NR | Yes | Moderate
O'Donnell et al, 2003^47^ | Yes | NR | Yes | NR | Unclear | Yes | Moderate
Pitschel-Walz et al, 2006^51^ | Yes | NR | Yes | Unclear | Yes | No | Moderate
Sajatovic et al, 2009^67^ | Yes | NR | Yes | NR | Yes | Yes | Moderate
Schulz et al, 2013^48^ | Yes | NR | Yes | Yes | Yes | Yes | Low
Valencia et al, 2010^52^ | Yes | NR | Yes | NR | Yes | Yes | Moderate
Velligan et al, 2008^60^ | Yes | NR | Yes | NR | Yes | Unclear | Moderate
Velligan et al, 2013^57^ | Yes | NR | Yes | NR | Yes | Yes | Low