# APPENDIX F PATIENT OUTCOME MEASURES

Abbreviation | Name | Description | Source
| Bech Rafaelsen Mania Scale | Assesses 11 items (elevated mood, pressure of speech, increased social contact, increased motor activity, sleep disturbances, social activities and distractibility, hostility and irritability, increased sexual activity, increased self-esteem, flight of thoughts, and noise level of speech and other vocal activity). | Self-report Administered by Psychologist
BPRS | Brief Psychiatric Rating Scale | Consists of items measuring positive symptoms, negative symptoms, depression and anxiety and manic excitement or disorganization with higher scores indicating greater severity. | Clinician assessed
BPRS–E | Brief Psychiatric Rating Scale – Expanded | Consists of 24 items measuring positive symptoms, negative symptoms, depression and anxiety and manic excitement or disorganization with higher scores indicating greater severity. | Clinician assessed
CGI | Clinical Global Impression scale | Rating scale designed to assess severity and the degree of change from the immediately preceding phase and from the worst phase of illness. Higher scores indicate greater severity. | Clinician assessed
CGI –SGH | Clinical Global Impression – Schizophrenia scale | Rating scale designed to assess severity and the degree of change from the immediately preceding phase and from the worst phase of illness. Higher scores indicate greater severity. | Clinician assessed
EQ-5D | EuroQoL | Assesses quality of life differences in patients with schizophrenia of differing degrees of severity. Higher values indicate higher quality of life ratings. | Self-report
GAF | Global Assessment of Functioning | Assesses function impairment caused by illness, with scores ranging from 0-100 and higher scores indicating higher levels of functioning. | Clinician rated
GAS | Global Assessment Scale | Assesses function impairment caused by illness, with scores ranging from 0-100 and higher scores indicating higher levels of functioning. | Clinician assessed
HAM-D | Hamilton Depression Rating Scale | 24 item scale assessing depression with scores ranging from 0-74, with higher scores indicating more severe depression. | Self-report
LEE | Level of Expressed Emotion | 30 item measure assessing critical comments, emotional over-involvement, and hostility. | Family rated
PANSS | Positive and Negative Syndrome Scale | Used to rate positive symptoms (range 7-49), negative symptoms (range 7-49), and general symptoms (range 15-112) of schizophrenia on a 7 point scale. Higher scores indicate higher severity. | Clinician assessed
QLF | Quality of Life Scale | 21-item scale based on semi-structured interview addressing intrapsychic foundations, interpersonal relations, instrumental role, and common objects and activities. | Clinician assessed
SAI | Schedule for Assessment of Insight | Scores expressed as a percentage of maximum insight. Higher values indicate greater insight | NR
SAI-E | Schedule for Assessment of Insight- Expanded | Scores expressed as a percentage of maximum insight. Higher values indicate greater insight | NR
SF-36 | Short Form Health Survey | Self-report multidimensional survey measure of health-related quality of life (QOL) and well-being. The mental component summary score (MCS) was used as the main QOL outcome measure, as it has been shown to have good sensitivity to change, which is uncommon among QOL measures. | Self-report
SOFAS | Social and Occupational Functioning Scale | Assesses social, work and school functioning. Higher sores increase higher adaptive functioning | Self-report
SWN | Subjective Well-being on Neuroleptic Treatment Scale | 20-item scale measuring mental functioning, social integration, emotional regulation, physical functioning, and self-control. | Self-report
UKU | UKU Side Effects Rating Scale | Semi-structured interview to assess the side effects of psychopharmacological interventions in the past 3 days. | Clinician assessed
WHOQOL-BREF | World Health Organization Quality of Life instrument – Abbreviated version | Quality of life questionnaire consisting of 26 items assessing physical, psychological, and social health and the environment. Scores for each domain are transformed to a 0-100 scale, with higher indicating better quality of life. | Self-report Administered by Psychologist
YMRS | Young Mania Rating Scale | Assesses mania, with scores ranging from 0-44 with higher scores indicating more severe mania. | Self-report