# APPENDIX E MEDICATION ADHERENCE OUTCOME MEASURES

Abbreviation | Name | Description | Source
AMQ | Attitude towards Medication Questionnaire | Semi-structured interview. Higher scores indicate a better attitude towards medication. | Clinician rated
CDR | Concentration to Dose Ratio | Serum concentration for primary antipsychotic with higher CDRs indicating better adherence. | Blood serum
CSRI | Client Service Receipt Inventory | Measures the frequency and duration of service contacts. | Self-report information, supplemented by case notes and hospital records
| Kemp scale^43^ | Compliance scale rated on a seven-point rating scale with higher scores indicating greater compliance | Multiple sources, including nurse assessed
DAI | Drug Attitude Inventory | Shown to be associated with degree of adherence to psychotropic medication, and is a true/false questionnaire that assesses patients' attitudes, experience, locus of control, attitudes towards medication. Scores range from 0-10 with higher scores indicating better attitudes towards medication. | Self-report
MAQ | Medication Adherence Questionnaire | 4-item measure that includes yes/no questions about forgetting to take medicine, carelessness with medicine, and discontinuation. A higher score indicates poorer treatment adherence. | Self-report
MARS | Medication Adherence Rating Scale | 10-item yes or no assessment of medication adherence, and was translated to Farsi and validated. (0-9 [one neutral question], higher scores indicate better adherence). | Self-report
MEMS | Medication Event Monitoring System | Medication vial cap that electronically records the date/time of bottle opening. | Electronic monitoring
| Morisky Scale | Assesses medication adherence, feelings about medication, with higher scores indicating poorer adherence | Self-report
SAI-C | Schedule for the Assessment of Insight - C | Therapist rating of adherence ranging from 1 (complete refusal) to 7 (active participation in treatment) based on a semi-structured interview. | Clinician rated
TRQ | Tablet Routine Questionnaire | Shows a high correlation with lithium levels and identifies partial and full adherence in the previous 7 and 30 days. | Self-report