# APPENDIX D STUDY SELECTION: INCLUSION/EXCLUSION CRITERIA FOR FULL-TEXT REVIEW

1. Language: Is the full text of the article in English?
  Yes Proceed to #2
  No Code X. STOP
2. Population: Is the population human participants?
  Yes Proceed to #3
  No Code X. Add code B if retaining for background/discussion. STOP
3. Population: Are the participants adults (18 or over) in general mental health settings (inpatient or outpatient – forensic patients/prisoners are excluded)?
  Yes Proceed to #4
  No Code X. Add code B if retaining for background/discussion. STOP
4. Medication Adherence Intervention: Does the article include information relevant to interventions specifically designed to increase medication adherence?
  Yes Proceed to #5
  No Code X. Add code B if retaining for background/discussion. STOP
5. Disease Condition: Does the intervention focus on patients with psychotic spectrum disorders, bipolar disorder, or posttraumatic stress disorder (PTSD)?
  Yes Proceed to #6
  No Code X. Add code B if retaining for background/discussion. STOP
6. Comparator: Is there a comparison group (eg, another intervention, no intervention, usual care), or are there more than two time points if no comparison group exists?
  Yes Proceed to #7
  No Code X. Add code B if retaining for background/discussion. STOP
7. Medication Adherence Outcomes: Are the outcomes objective (eg, medication container with electronic monitoring [eg, MEMS], pill counts, biological markers, observed intake, medication possession ratio, medication plasma level, electronic ingestible event marker) or measured subjectively by a [underlined: validated] patient self-report scale or measure (eg, not patient self-report or report by caregiver, case manager, not clinician's view on adherence based on therapeutic response).
  Yes Proceed to #9
  No Code X. Add code B if retaining for background/discussion. STOP
8. Clinical Outcome: Is a clinical outcome related to the medication adherence intervention and the medication adherence outcome reported?
  Yes Proceed to #10
  No Code X. Add code B if retaining for background/discussion. STOP
9. Study Design: Is the study design a cross-sectional study or a simple pre-post, or qualitative study, or a non-systematic literature review, case study, case series, case report, commentary, or letter to the editor??
  Yes Code X. Add code B if retaining for background/discussion. STOP
  No Code R. Stop
  Unknown Code U. Stop