# APPENDIX C STUDY SELECTION: INCLUSION/EXCLUSION CRITERIA FOR TITLE/ABSTRACT REVIEW

Instructions:

- In Abstrackr, a √ designates a study as included, a ? as unknown, and an X will exclude the study. See table below for inclusion/exclusion criteria.
- When you are looking at an abstract, you will see a box to the left that is titled tags & notes. Please click “tag study” and tag the following:
  ○ If you are excluding a study or are unsure, but think it is appropriate background information, please tag the study as B
  ○ If the study meets all inclusion criteria except for study design, and the study is a cross-sectional study, please exclude the study but add the tag CS.
  ○ If the study meets all inclusion criteria except for study design, and the study is a systematic review, please exclude the study but add the tag SR.
- On the bottom of the screen, you will see a series of thumbs ups and thumbs downs next to a box with the word “term” next to it. Adding a term highlights it in both the abstract you are viewing, as well as all subsequent abstracts viewed by yourself and others. This allows for faster screening. A thumbs up indicates that it is a relevant term (two thumbs up = highly relevant), and a thumbs down indicates that the term is not relevant. Using these terms is optional; however, if you do see terms in abstracts that would suggest that the study is relevant or not (eg, specific med adherence outcomes, “adult,” schizophrenia, bipolar, PTSD, common clinical outcomes, etc) that might make the screening process faster for everyone, feel free to use them!
- Please note – if you are unsure about whether the study meets criteria (eg, population specifies mental health disorders, but not which ones, or doesn't state what they used to measure med adherence, please code ?, and we'll look at the full text).

While likely unnecessary, if you feel you need more guidance on the use of Abstrackr, see an instructional video: https://www.youtube.com/watch?v = 34Yb-ac9ULM

Include (Code √) if the study is/does (all criteria below must be met): | Exclude (Code X) if the study is/does/has (any of the below):
Language: English | Language: Non-English Language
Population: Human Participants | Population: Non-human “participants”
Age: Adults 18+ | Age: < 18 years of age
Condition: Includes individuals diagnosed with Psychotic Spectrum Disorder –OR- Bipolar Disorder – OR- PTSD | Condition: [underlined: No diagnosis] of Psychotic Spectrum Disorder –OR- Bipolar Disorder – OR- PTSD
Intervention: Includes interventions [underlined: designed specifically or are being specifically used to increase medication adherence] | Intervention: No med adherence intervention, or the interventions are [underlined: not specifically designed] or used in a way to [underlined: specifically addresses] medication adherence (eg, broader more general group therapy or other types of therapies)
Comparator: Includes a comparison group (eg, another intervention, no intervention, usual care). | Comparator: [underlined: No comparison] group
Med Adherence Outcome(s): Must be the [underlined: primary] outcome –AND- must be an [underlined: objective] outcome (eg, medication container with electronic monitoring, pill counts, biological marker, observed intake, medication possession ratio [MPR], medication plasma level, electronic ingestible event marker) –OR- a [underlined: validated subjective outcome] (eg, self-report measure or scale such as the Morisky-9 [MMAS-8], Morisky-4 [MMAS-4 or MAQ]) | Med Adherence Outcome(s): Not the primary outcome –OR- Patient self-report, caregiver report, case manager report, clinician's view based on therapeutic response, and other [underlined: non-validated subjective outcomes].
Patient Outcome: Includes a [underlined: patient outcome] that is related to the medication adherence intervention AND medication adherence outcome reported. | Patient Outcome: [underlined: No patient outcome] that is related to the medication adherence intervention AND medication adherence outcome reported.
Study Design: Trials, case-controlled, and cohort studies | Study Design: Reviews (systematic or non-systematic), case series, case study, case report, qualitative, commentary, letter to the editor, and any other study design not meeting inclusion criteria.

Note. If at any time you are unsure of whether the study should be included, code ?