# APPENDIX B SEARCH STRATEGIES

## DATABASE STRATEGY

- Medline - Ovid
- PubMed [publisher] segment – National Library of Medicine
- EMBASE – Elsevier.com
- PsycINFO – Ovid
- Cochrane Library (Ovid EBM Reviews): Cochrane Central Register of Controlled Trials; Cochrane Database of Systematic Reviews; Database of Abstracts of Reviews of Effects; Health Technology Assessment; NHS Economic Evaluation Database
- CINAHL - EBSCOHost
- Conference Papers Index - ProQuest
- Dissertations & Theses - ProQuest

## GREY LITERATURE STRATEGY

- ClinicalTrials.gov - http://www.clinicaltrials.gov
- WHO ICTRP - http://apps.who.int/trialsearch/
- ISRCTN Registry - http://www.isrctn.com/

## INDIVIDUAL DATABASE SEARCH STRATEGIES

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946 to January Week 3 2015, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations January 27, 2015

Date Searched: January 29, 2015

1 | Medication Adherence/ | 8162
2 | Patient Compliance/ | 47223
3 | Medication Reconciliation/ | 379
4 | Medication Therapy Management/ | 740
5 | Treatment Refusal/ | 10659
6 | (((medication^*^ or pharmaceutical^*^ or drug^*^ or pharmacotherap^*^ or regimen^*^ or therap^*^ or treat^*^ or prophylaxis or psychotropic or psychopharmac^*^ or pharmacolog^*^ or antipsychot^*^ or anti-psychot^*^ or neuroleptic^*^ or mood stabilizer^*^ or antiepileptic^*^ or anti-epileptic^*^ or anticonvulsant^*^ or anti-convulsant^*^ or poor^*^ or patient^*^ or client^*^ or refus^*^) adj3 (adheren^*^ or non-adheren^*^ or nonadheren^*^ or complian^*^ or non-complian^*^ or noncomplian^*^ or persist^*^ or non-persist^*^ or nonpersist^*^ or reconciliat^*^)) or medication therapy management).ti,ab. | 83952
7 | or/1-6 | 128965
8 | Psychotic Disorders/ | 32480
9 | Schizophrenia/ | 82350
10 | Schizophrenia, catatonic/ | 529
11 | Schizophrenia, disorganized/ | 505
12 | Schizophrenia, paranoid/ | 3674
13 | Shared Paranoid Disorder/ | 283
14 | Schizoid Personality Disorder/ | 565
15 | Schizotypal Personality Disorder/ | 2198
16 | Affective disorders, psychotic/ | 2105
17 | Bipolar Disorder/ | 31621
18 | Cyclothymic Disorder/ | 517
19 | Stress disorders, traumatic/ | 471
20 | Combat Disorders/ | 2589
21 | Stress disorders, post-traumatic/ | 21646
22 | Stress disorders, traumatic, acute/ | 316
23 | (psychotic or schizotyp^*^ or schizophren^*^ or schizoid^*^ or schizoaffective or bipolar or mania^*^ or hypomania^*^ or hypo-mania^*^ or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or ((severe^*^ or serious^*^ or chronic^*^ or persistent^*^) adj mental^*^ ill^*^)).ti,ab. | 177009
24 | or/8-23 | 225382
25 | Policy Making/ | 12464
26 | Public Policy/ | 28025
27 | “State Health Planning and Development Agencies”/ | 186
28 | Insurance Claim Review/ | 4595
29 | “Medicare Part D”/ | 603
30 | Medicaid/ | 19453
31 | Health Services Accessibility/ | 52115
32 | Health Policy/ | 51267
33 | “Formularies as Topic”/ | 1787
34 | Community Pharmacy Services/ | 2925
35 | Cost-sharing/ | 1993
36 | “Health Benefit Plans, Employee”/ | 9199
37 | “Insurance, Pharmaceutical Services”/ | 3574
38 | Managed Care Programs/ | 23432
39 | “Health Maintenance Organizations”/og | 3495
40 | “Primary Health Care”/ec, og | 13631
41 | Prescription Drugs/ | 3113
42 | Polypharmacy/ | 2516
43 | Drug Costs/ | 12338
44 | Drug Packaging/ | 4272
45 | Health Services Research/ | 31057
46 | Medical Indigency/ | 3480
47 | Program Development/ | 23021
48 | Disease Management/ | 12378
49 | “Pharmacy Service, Hospital”/ | 9942
50 | “Drug Administration Schedule”/ | 85246
51 | (intervention or interventions or program^*^ or reduce or reduction or patient-level^*^ or system-level^*^ or policy-level^*^ or provider^*^ or strateg^*^ or enhanc^*^ or improv^*^ or increas^*^ or device^*^ or pill^*^ or packag^*^ or policy or policies or benefit^*^ or insurance or insured or contain^*^ or co-pay^*^ or copay^*^ or cost^*^ or pharmacy^*^ or pharmacies^*^ or pharmacist^*^ or pharmacologist^*^ or remind^*^ or refill^*^ or refill^*^ or inject^*^ or depot^*^ or LAI or dosing or tele^*^ or email^*^ or text^*^ or virtual^*^ or computer^*^ or electronic^*^ or internet or ehealth or online or interactive^*^ or interdisciplinary or inter-disciplinary or technolog^*^ or monitor^*^ or record^*^ or data^*^ or manag^*^ or self-manag^*^ or counsel^*^ or therap^*^ or alliance or coordinat^*^ or co-ordinat^*^ or communicat^*^ or cognitive or interview^*^ or psychosocial or psycho-social or multicomponent or multi-component or support^*^ or tailor^*^ or coach^*^ or diary or diaries or behavioral or behavioural or family^*^ or families^*^ or peer^*^ or communit^*^ or decision^*^ or educat^*^ or psychoeducation^*^ or psychoeducation^*^ or train^*^ or incentiv^*^ or facilitat^*^ or supervised treatment in out-patients for schizophren^*^ or STOPS or ((reduc^*^ or remov^*^) adj2 barrier^*^) or “30-day Adherence Question” or “5-item Questionnaire” or “Adherence Attitude Inventory” or “Adherence Question” or “Adherence Questionnaire” or “Adherence Self-Report Questionnaire” or ASRQ or “Adherence Starts with Knowledge-12” or ASK-12 or “Adherence Starts with Knowledge-20” or ASK-20 or “Adherence to Refills and Medications Scale” or “Adherence Visual Analogue Scale” or “Beliefs about Medicines Questionnaire” or “Beliefs and Behaviour Questionnaire” or - “Beliefs and Behavior Questionnaire” or “Brief Adherence Rating Scale” or “Brief Evaluation of Medication Influences and Beliefs” or BEMIB or “Brief Medication Questionnaire” or “Brooks Medication Adherence Scale” or BMAS or “Centre for Adherence Support Evaluation” or “CASE Adherence Index” or “CASE Index” or “Compliance Questionnaire Rheumatology” or “Drug Attitude Inventory” or “Hill-Bone Compliance Scale” or “Immunosuppressant Therapy Adherence Scale” or ITAS or “Maastricht Utrecht Adherence in Hypertension Questionnaire” or MUAH or “Medication Adherence Assessment Tool” or MAAT or “Medication Adherence Questionnaire” or MAQ or “Medication Adherence Reasons Scale” or “Medication Adherence Report Scale^*^” or “Medication Adherence Self-Efficacy Scale” or MASES or “Medication Adherence Self-Efficacy Scale Revised” or MASES-R or “Morisky Medication Adherence Scale” or MMAS or “Modified Morisky Scale” or MMS or Morisky-8 or MMS-8 or Morisky-4 or MMS-4 or “Osteoporosis-Specific Morisky Medication Adherence Scale” or OS-MMAS or “Reported Adherence to Medicine Scale” or “Self-Reported Adherence Questionnaire” or SERAD or “Simplified Medication Adherence Questionnaire” or SMAQ or “Stages of Change for Adherence” or SOCA or “The Patterns of Asthma Medication Use Questionnaire” or “The Self-Efficacy for Appropriate Medication Use Scale”).ti,ab. | 12030466
52 | or/25-51 | 12133327
53 | and/7,24,52 | 4722
54 | remove duplicates from 53 | 4705
55 | animals/ not humans/ | 3879816
56 | 54 not 55 | 4675
57 | limit 56 to “all child (0 to 18 years)” | 753
58 | limit 57 to “all adult (19 plus years)” | 654
59 | 57 not 58 | 99
60 | 56 not 59 | 4576
61 | limit 60 to (comment or editorial or letter) | 93
62 | 60 not 61 | 4483
63 | limit 62 to english language | 4057

PubMed - [Publisher subset search]

http://www.ncbi.nlm.nih.gov/pubmed/

Date Searched: January 29, 2015

#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((((((medication^*^[Title/Abstract] OR pharmaceutical^*^[Title/Abstract] OR drug^*^[Title/Abstract] OR pharmacotherap^*^[Title/Abstract] OR regimen^*^[Title/Abstract] OR therap^*^[Title/Abstract] OR treat^*^[Title/Abstract] OR prophylaxis[Title/Abstract] OR psychotropic[Title/Abstract] OR psychopharmac^*^[Title/Abstract] OR pharmacolog^*^[Title/Abstract] OR antipsychot^*^[Title/Abstract] OR anti-psychot^*^[Title/Abstract] OR neuroleptic^*^[Title/Abstract] OR mood stabilizer^*^[Title/Abstract] OR antiepileptic^*^[Title/Abstract] OR anti-epileptic^*^[Title/Abstract] OR anticonvulsant^*^[Title/Abstract] OR anti-convulsant^*^[Title/Abstract] OR poor^*^[Title/Abstract] OR patient^*^[Title/Abstract] OR client^*^[Title/Abstract] OR refus^*^[Title/Abstract])) AND (adheren^*^[Title/Abstract] OR non-adheren^*^[Title/Abstract] OR nonadheren^*^[Title/Abstract] OR complian^*^[Title/Abstract] OR non-complian^*^[Title/Abstract] OR noncomplian^*^[Title/Abstract] OR persist^*^[Title/Abstract] OR non-persist^*^[Title/Abstract] OR nonpersist^*^[Title/Abstract] OR reconciliat^*^[Title/Abstract])) AND publisher [sb])) OR ((medication therapy management[Title/Abstract]) AND publisher [sb]))) AND (((psychotic[Title/Abstract] OR schizotyp^*^[Title/Abstract] OR schizophren^*^[Title/Abstract] OR schizoid^*^[Title/Abstract] OR schizoaffective[Title/Abstract] OR bipolar[Title/Abstract] OR mania^*^[Title/Abstract] OR hypomania^*^[Title/Abstract] OR hypo-mania^*^[Title/Abstract] OR manic[Title/Abstract] OR cyclothymic[Title/Abstract] OR PTSD[Title/Abstract] OR post-traumatic stress[Title/Abstract] OR posttraumatic stress[Title/Abstract] OR severe^*^ mental^*^ ill^*^[Title/Abstract] OR serious^*^ mental^*^ ill^*^[Title/Abstract] OR chronic^*^ mental^*^ ill^*^[Title/Abstract] OR persistent^*^ mental^*^ ill^*^[Title/Abstract])) AND publisher [sb])) AND (((intervention[Title/Abstract] OR interventions[Title/Abstract] OR program^*^[Title/Abstract] OR reduce[Title/Abstract] OR reduction[Title/Abstract] OR patient-level^*^[Title/Abstract] OR system-level^*^[Title/Abstract] OR policy-level^*^[Title/Abstract] OR provider^*^[Title/Abstract] OR strateg^*^[Title/Abstract] OR enhanc^*^[Title/Abstract] OR improv^*^[Title/Abstract] OR increas^*^[Title/Abstract] OR device^*^[Title/Abstract] OR pill^*^[Title/Abstract] OR packag^*^[Title/Abstract] OR policy[Title/Abstract] OR policies[Title/Abstract] OR benefit^*^[Title/Abstract] OR insurance[Title/Abstract] OR insured[Title/Abstract] OR contain^*^[Title/Abstract] OR co-pay^*^[Title/Abstract] OR copay^*^[Title/Abstract] OR cost^*^[Title/Abstract] OR pharmacy^*^[Title/Abstract] OR pharmacies^*^[Title/Abstract] OR pharmacist^*^[Title/Abstract] OR pharmacologist^*^[Title/Abstract] OR remind^*^[Title/Abstract] OR refill^*^[Title/Abstract] OR re-fill^*^[Title/Abstract] OR inject^*^[Title/Abstract] OR depot^*^[Title/Abstract] OR LAI[Title/Abstract] OR dosing[Title/Abstract] OR tele^*^[Title/Abstract] OR email^*^[Title/Abstract] OR text^*^[Title/Abstract] OR virtual^*^[Title/Abstract] OR computer^*^[Title/Abstract] OR electronic^*^[Title/Abstract] OR internet[Title/Abstract] OR ehealth[Title/Abstract] OR online[Title/Abstract] OR interactive^*^[Title/Abstract] OR interdisciplinary[Title/Abstract] OR inter-disciplinary[Title/Abstract] OR technolog^*^[Title/Abstract] OR monitor^*^[Title/Abstract] OR record^*^[Title/Abstract] OR data^*^[Title/Abstract] OR manag^*^[Title/Abstract] OR self-manag^*^[Title/Abstract] OR counsel^*^[Title/Abstract] OR therap^*^[Title/Abstract] OR alliance[Title/Abstract] OR coordinat^*^[Title/Abstract] OR co-ordinat^*^[Title/Abstract] OR communicat^*^[Title/Abstract] OR cognitive[Title/Abstract] OR interview^*^[Title/Abstract] OR psychosocial[Title/Abstract] OR psycho-social[Title/Abstract] OR multicomponent[Title/Abstract] OR multi-component[Title/Abstract] OR support^*^[Title/Abstract] OR tailor^*^[Title/Abstract] OR coach^*^[Title/Abstract] OR diary[Title/Abstract] OR diaries[Title/Abstract] OR behavioral[Title/Abstract] OR behavioural[Title/Abstract] OR family^*^[Title/Abstract] OR families^*^[Title/Abstract] OR peer^*^[Title/Abstract] OR communit^*^[Title/Abstract] OR decision^*^[Title/Abstract] OR educat^*^[Title/Abstract] OR psychoeducation^*^[Title/Abstract] OR psychoeducation^*^[Title/Abstract] OR train^*^[Title/Abstract] OR incentiv^*^[Title/Abstract] OR “facilitat^*^[Title/Abstract] OR supervised treatment in out-patients for schizophren^*^”[Title/Abstract] OR STOPS[Title/Abstract] OR reduc^*^ barrier^*^[Title/Abstract] OR remov^*^ barrier^*^[Title/Abstract] OR “30-day Adherence Question”[Title/Abstract] OR “5-item Questionnaire”[Title/Abstract] OR “Adherence Attitude Inventory”[Title/Abstract] OR “Adherence Question”[Title/Abstract] OR “Adherence Questionnaire”[Title/Abstract] OR “Adherence Self-Report Questionnaire”[Title/Abstract] OR ASRQ[Title/Abstract] OR “Adherence Starts with Knowledge-12”[Title/Abstract] OR ASK-12[Title/Abstract] OR “Adherence Starts with Knowledge-20”[Title/Abstract] OR ASK-20[Title/Abstract] OR “Adherence to Refills[Title/Abstract] AND Medications Scale”[Title/Abstract] OR “Adherence Visual Analogue Scale”[Title/Abstract] OR “Beliefs about Medicines Questionnaire”[Title/Abstract] OR “Beliefs[Title/Abstract] AND Behaviour Questionnaire”[Title/Abstract] OR “Beliefs[Title/Abstract] AND Behavior Questionnaire”[Title/Abstract] OR “Brief Adherence Rating Scale”[Title/Abstract] OR “Brief Evaluation of Medication Influences[Title/Abstract] AND Beliefs”[Title/Abstract] OR BEMIB[Title/Abstract] OR “Brief Medication Questionnaire”[Title/Abstract] OR “Brooks Medication Adherence Scale”[Title/Abstract] OR BMAS[Title/Abstract] OR “Centre for Adherence Support Evaluation”[Title/Abstract] OR “CASE Adherence Index”[Title/Abstract] OR “CASE Index”[Title/Abstract] OR “Compliance Questionnaire Rheumatology”[Title/Abstract] OR “Drug Attitude Inventory”[Title/Abstract] OR “Hill-Bone Compliance Scale”[Title/Abstract] OR “Immunosuppressant Therapy Adherence Scale”[Title/Abstract] OR ITAS[Title/Abstract] OR “Maastricht Utrecht Adherence in Hypertension Questionnaire”[Title/Abstract] OR MUAH[Title/Abstract] OR “Medication Adherence Assessment Tool”[Title/Abstract] OR MAAT[Title/Abstract] OR “Medication Adherence Questionnaire”[Title/Abstract] OR MAQ[Title/Abstract] OR “Medication Adherence Reasons Scale”[Title/Abstract] OR “Medication Adherence Report Scale^*^”[Title/Abstract] OR “Medication Adherence Self-Efficacy Scale”[Title/Abstract] OR MASES[Title/Abstract] OR “Medication Adherence Self-Efficacy Scale Revised”[Title/Abstract] OR MASES-R[Title/Abstract] OR “Morisky Medication Adherence Scale”[Title/Abstract] OR MMAS[Title/Abstract] OR “Modified Morisky Scale”[Title/Abstract] OR MMS[Title/Abstract] OR Morisky-8[Title/Abstract] OR MMS-8[Title/Abstract] OR Morisky-4[Title/Abstract] OR MMS-4[Title/Abstract] OR “Osteoporosis-Specific Morisky Medication Adherence Scale”[Title/Abstract] OR OS-MMAS[Title/Abstract] OR “Reported Adherence to Medicine Scale”[Title/Abstract] OR “Self-Reported Adherence Questionnaire”[Title/Abstract] OR SERAD[Title/Abstract] OR “Simplified Medication Adherence Questionnaire”[Title/Abstract] OR SMAQ[Title/Abstract] OR “Stages of Change for Adherence”[Title/Abstract] OR SOCA[Title/Abstract] OR “The Patterns of Asthma Medication Use Questionnaire”[Title/Abstract] OR “The Self-Efficacy for Appropriate Medication Use Scale”[Title/Abstract])) AND publisher [sb]) | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((intervention[Title/Abstract] OR interventions[Title/Abstract] OR program^*^[Title/Abstract] OR reduce[Title/Abstract] OR reduction[Title/Abstract] OR patient-level^*^[Title/Abstract] OR system-level^*^[Title/Abstract] OR policy-level^*^[Title/Abstract] OR provider^*^[Title/Abstract] OR strateg^*^[Title/Abstract] OR enhanc^*^[Title/Abstract] OR improv^*^[Title/Abstract] OR increas^*^[Title/Abstract] OR device^*^[Title/Abstract] OR pill^*^[Title/Abstract] OR packag^*^[Title/Abstract] OR policy[Title/Abstract] OR policies[Title/Abstract] OR benefit^*^[Title/Abstract] OR insurance[Title/Abstract] OR insured[Title/Abstract] OR contain^*^[Title/Abstract] OR co-pay^*^[Title/Abstract] OR copay^*^[Title/Abstract] OR cost^*^[Title/Abstract] OR pharmacy^*^[Title/Abstract] OR pharmacies^*^[Title/Abstract] OR pharmacist^*^[Title/Abstract] OR pharmacologist^*^[Title/Abstract] OR remind^*^[Title/Abstract] OR refill^*^[Title/Abstract] OR re-fill^*^[Title/Abstract] OR inject^*^[Title/Abstract] OR depot^*^[Title/Abstract] OR LAI[Title/Abstract] OR dosing[Title/Abstract] OR tele^*^[Title/Abstract] OR email^*^[Title/Abstract] OR text^*^[Title/Abstract] OR virtual^*^[Title/Abstract] OR computer^*^[Title/Abstract] OR electronic^*^[Title/Abstract] OR internet[Title/Abstract] OR ehealth[Title/Abstract] OR online[Title/Abstract] OR interactive^*^[Title/Abstract] OR interdisciplinary[Title/Abstract] OR interdisciplinary[ Title/Abstract] OR technolog^*^[Title/Abstract] OR monitor^*^[Title/Abstract] OR record^*^[Title/Abstract] OR data^*^[Title/Abstract] OR manag^*^[Title/Abstract] OR self-manag^*^[Title/Abstract] OR counsel^*^[Title/Abstract] OR therap^*^[Title/Abstract] OR alliance[Title/Abstract] OR coordinat^*^[Title/Abstract] OR co-ordinat^*^[Title/Abstract] OR communicat^*^[Title/Abstract] OR cognitive[Title/Abstract] OR interview^*^[Title/Abstract] OR psychosocial[Title/Abstract] OR psycho-social[Title/Abstract] OR multicomponent[Title/Abstract] OR multi-component[Title/Abstract] OR support^*^[Title/Abstract] OR tailor^*^[Title/Abstract] OR coach^*^[Title/Abstract] OR diary[Title/Abstract] OR diaries[Title/Abstract] OR behavioral[Title/Abstract] OR behavioural[Title/Abstract] OR family^*^[Title/Abstract] OR families^*^[Title/Abstract] OR peer^*^[Title/Abstract] OR communit^*^[Title/Abstract] OR decision^*^[Title/Abstract] OR educat^*^[Title/Abstract] OR psychoeducation^*^[Title/Abstract] OR psychoeducation^*^[Title/Abstract] OR train^*^[Title/Abstract] OR incentiv^*^[Title/Abstract] OR “facilitat^*^[Title/Abstract] OR supervised treatment in out-patients for schizophren^*^”[Title/Abstract] OR STOPS[Title/Abstract] OR reduc^*^ barrier^*^[Title/Abstract] OR remov^*^ barrier^*^[Title/Abstract] OR “30-day Adherence Question”[Title/Abstract] OR “5-item Questionnaire”[Title/Abstract] OR “Adherence Attitude Inventory”[Title/Abstract] OR “Adherence Question”[Title/Abstract] OR “Adherence Questionnaire”[Title/Abstract] OR “Adherence Self-Report Questionnaire”[Title/Abstract] OR ASRQ[Title/Abstract] OR “Adherence Starts with Knowledge-12”[Title/Abstract] OR ASK-12[Title/Abstract] OR “Adherence Starts with Knowledge-20”[Title/Abstract] OR ASK-20[Title/Abstract] OR “Adherence to Refills[Title/Abstract] AND Medications Scale”[Title/Abstract] OR “Adherence Visual Analogue Scale”[Title/Abstract] OR “Beliefs about Medicines Questionnaire”[Title/Abstract] OR “Beliefs[Title/Abstract] AND Behaviour Questionnaire”[Title/Abstract] OR “Beliefs[Title/Abstract] AND Behavior Questionnaire”[Title/Abstract] OR “Brief Adherence Rating Scale”[Title/Abstract] OR “Brief Evaluation of Medication Influences[Title/Abstract] AND Beliefs”[Title/Abstract] OR BEMIB[Title/Abstract] OR “Brief Medication Questionnaire”[Title/Abstract] OR “Brooks Medication Adherence Scale”[Title/Abstract] OR BMAS[Title/Abstract] OR “Centre for Adherence Support Evaluation”[Title/Abstract] OR “CASE Adherence Index”[Title/Abstract] OR “CASE Index”[Title/Abstract] OR “Compliance Questionnaire Rheumatology”[Title/Abstract] OR “Drug Attitude Inventory”[Title/Abstract] OR “Hill-Bone Compliance Scale”[Title/Abstract] OR “Immunosuppressant Therapy Adherence Scale”[Title/Abstract] OR ITAS[Title/Abstract] OR “Maastricht Utrecht Adherence in Hypertension Questionnaire”[Title/Abstract] OR MUAH[Title/Abstract] OR “Medication Adherence Assessment Tool”[Title/Abstract] OR MAAT[Title/Abstract] OR “Medication Adherence Questionnaire”[Title/Abstract] OR MAQ[Title/Abstract] OR “Medication Adherence Reasons Scale”[Title/Abstract] OR “Medication Adherence Report Scale^*^”[Title/Abstract] OR “Medication Adherence Self-Efficacy Scale”[Title/Abstract] OR MASES[Title/Abstract] OR “Medication Adherence Self-Efficacy Scale Revised”[Title/Abstract] OR MASES-R[Title/Abstract] OR “Morisky Medication Adherence Scale”[Title/Abstract] OR MMAS[Title/Abstract] OR “Modified Morisky Scale”[Title/Abstract] OR MMS[Title/Abstract] OR Morisky-8[Title/Abstract] OR MMS-8[Title/Abstract] OR Morisky-4[Title/Abstract] OR MMS-4[Title/Abstract] OR “Osteoporosis-Specific Morisky Medication Adherence Scale”[Title/Abstract] OR OS-MMAS[Title/Abstract] OR “Reported Adherence to Medicine Scale”[Title/Abstract] OR “Self-Reported Adherence Questionnaire”[Title/Abstract] OR SERAD[Title/Abstract] OR “Simplified Medication Adherence Questionnaire”[Title/Abstract] OR SMAQ[Title/Abstract] OR “Stages of Change for Adherence”[Title/Abstract] OR SOCA[Title/Abstract] OR “The Patterns of Asthma Medication Use Questionnaire”[Title/Abstract] OR “The Self-Efficacy for Appropriate Medication Use Scale”[Title/Abstract])) AND publisher [sb] | 4569 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((psychotic[Title/Abstract] OR schizotyp^*^[Title/Abstract] OR schizophren^*^[Title/Abstract] OR schizoid^*^[Title/Abstract] OR schizoaffective[Title/Abstract] OR bipolar[Title/Abstract] OR mania^*^[Title/Abstract] OR hypomania^*^[Title/Abstract] OR hypo-mania^*^[Title/Abstract] OR manic[Title/Abstract] OR cyclothymic[Title/Abstract] OR PTSD[Title/Abstract] OR post-traumatic stress[Title/Abstract] OR posttraumatic stress[Title/Abstract] OR severe^*^ mental^*^ ill^*^[Title/Abstract] OR serious^*^ mental^*^ ill^*^[Title/Abstract] OR chronic^*^ mental^*^ ill^*^[Title/Abstract] OR persistent^*^ mental^*^ ill^*^[Title/Abstract])) AND publisher [sb] | 608 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((medication^*^[Title/Abstract] OR pharmaceutical^*^[Title/Abstract] OR drug^*^[Title/Abstract] OR pharmacotherap^*^[Title/Abstract] OR regimen^*^[Title/Abstract] OR therap^*^[Title/Abstract] OR treat^*^[Title/Abstract] OR prophylaxis[Title/Abstract] OR psychotropic[Title/Abstract] OR psychopharmac^*^[Title/Abstract] OR pharmacolog^*^[Title/Abstract] OR antipsychot^*^[Title/Abstract] OR anti-psychot^*^[Title/Abstract] OR neuroleptic^*^[Title/Abstract] OR mood stabilizer^*^[Title/Abstract] OR antiepileptic^*^[Title/Abstract] OR anti-epileptic^*^[Title/Abstract] OR anticonvulsant^*^[Title/Abstract] OR anti-convulsant^*^[Title/Abstract] OR poor^*^[Title/Abstract] OR patient^*^[Title/Abstract] OR client^*^[Title/Abstract] OR refus^*^[Title/Abstract])) AND (adheren^*^[Title/Abstract] OR non-adheren^*^[Title/Abstract] OR nonadheren^*^[Title/Abstract] OR complian^*^[Title/Abstract] OR non-complian^*^[Title/Abstract] OR noncomplian^*^[Title/Abstract] OR persist^*^[Title/Abstract] OR non-persist^*^[Title/Abstract] OR nonpersist^*^[Title/Abstract] OR reconciliat^*^[Title/Abstract])) AND publisher [sb])) OR ((medication therapy management[Title/Abstract]) AND publisher [sb]) | 6556 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (medication therapy management[Title/Abstract]) AND publisher [sb] | 20 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((medication^*^[Title/Abstract] OR pharmaceutical^*^[Title/Abstract] OR drug^*^[Title/Abstract] OR pharmacotherap^*^[Title/Abstract] OR regimen^*^[Title/Abstract] OR therap^*^[Title/Abstract] OR treat^*^[Title/Abstract] OR prophylaxis[Title/Abstract] OR psychotropic[Title/Abstract] OR psychopharmac^*^[Title/Abstract] OR pharmacolog^*^[Title/Abstract] OR antipsychot^*^[Title/Abstract] OR anti-psychot^*^[Title/Abstract] OR neuroleptic^*^[Title/Abstract] OR mood stabilizer^*^[Title/Abstract] OR antiepileptic^*^[Title/Abstract] OR anti-epileptic^*^[Title/Abstract] OR anticonvulsant^*^[Title/Abstract] OR anti-convulsant^*^[Title/Abstract] OR poor^*^[Title/Abstract] OR patient^*^[Title/Abstract] OR client^*^[Title/Abstract] OR refus^*^[Title/Abstract])) AND (adheren^*^[Title/Abstract] OR non-adheren^*^[Title/Abstract] OR nonadheren^*^[Title/Abstract] OR complian^*^[Title/Abstract] OR non-complian^*^[Title/Abstract] OR noncomplian^*^[Title/Abstract] OR persist^*^[Title/Abstract] OR non-persist^*^[Title/Abstract] OR nonpersist^*^[Title/Abstract] OR reconciliat^*^[Title/Abstract])) AND publisher [sb] | 6539 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)

Ovid PsycINFO 1806 to January Week 4 2015

Date searched: January 29, 2015

1 | (((medication^*^ or pharmaceutical^*^ or drug^*^ or pharmacotherap^*^ or regimen^*^ or therap^*^ or treat^*^ or prophylaxis or psychotropic or psychopharmac^*^ or pharmacolog^*^ or antipsychot^*^ or anti-psychot^*^ or neuroleptic^*^ or mood stabilizer^*^ or antiepileptic^*^ or anti-epileptic^*^ or anticonvulsant^*^ or anti-convulsant^*^ or poor^*^ or patient^*^ or client^*^ or refus^*^) adj3 (adheren^*^ or non-adheren^*^ or nonadheren^*^ or complian^*^ or non-complian^*^ or noncomplian^*^ or persist^*^ or non-persist^*^ or nonpersist^*^ or reconciliat^*^)) or medication therapy management or treatment refusal).ti,ab. | 18146
2 | psychosis/ or acute psychosis/ or affective psychosis/ or alcoholic psychosis/ or capgras syndrome/ or childhood psychosis/ or chronic psychosis/ or experimental psychosis/ or hallucinosis/ or “paranoia (psychosis)”/ or postpartum psychosis/ or reactive psychosis/ or senile psychosis/ or toxic psychoses/ | 24899
3 | schizophrenia/ or acute schizophrenia/ or catatonic schizophrenia/ or paranoid schizophrenia/ or process schizophrenia/ or “schizophrenia (disorganized type)”/ or schizophreniform disorder/ or undifferentiated schizophrenia/ or Folie A Deux/ | 73717
4 | exp Schizoid Personality Disorder/ | 608
5 | schizotypal personality disorder/ or schizotypy/ | 1533
6 | bipolar disorder/ or cyclothymic personality/ | 20400
7 | mania/ or hypomania/ | 5245
8 | posttraumatic stress disorder/ | 22851
9 | acute stress disorder/ | 463
10 | (psychotic or schizotyp^*^ or schizophren^*^ or schizoid^*^ or schizoaffective or bipolar or mania^*^ or hypomania^*^ or hypo-mania^*^ or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or ((severe^*^ or serious^*^ or chronic^*^ or persistent^*^) adj mental^*^ ill^*^)).ti,ab. | 184993
11 | or/2-10 | 196933
12 | exp Policy Making/ or exp Government Policy Making/ or exp Health Care Services/ or exp Public Health Services/ or exp Mental Health Services/ or exp Health Education/ or exp Mental Health Programs/ or exp Public Health/ or exp Health Care Policy/ or exp Government Agencies/ | 167408
13 | health insurance/ or employee health insurance/ or fee for service/ or health maintenance organizations/ or medicaid/ or medicare/ or “underinsured (health insurance)”/ or “uninsured (health insurance)”/ or managed care/ | 9796
14 | exp Primary Health Care/ | 13140
15 | exp Prescription Drugs/ | 2777
16 | exp Polypharmacy/ | 816
17 | health care costs/ | 7325
18 | exp Program Development/ | 7372
19 | exp Disease Management/ | 4344
20 | pharmacists/ or medical personnel/ | 6007
21 | (intervention or interventions or program^*^ or reduce or reduction or patient-level^*^ or system-level^*^ or policy-level^*^ or provider^*^ or strateg^*^ or enhanc^*^ or improv^*^ or increas^*^ or device^*^ or pill^*^ or packag^*^ or policy or policies or benefit^*^ or insurance or insured or contain^*^ or co-pay^*^ or copay^*^ or cost^*^ or pharmacy^*^ or pharmacies^*^ or pharmacist^*^ or pharmacologist^*^ or remind^*^ or refill^*^ or re-fill^*^ or inject^*^ or depot^*^ or LAI or dosing or tele^*^ or email^*^ or text^*^ or virtual^*^ or computer^*^ or electronic^*^ or internet or ehealth or online or interactive^*^ or interdisciplinary or inter-disciplinary or technolog^*^ or monitor^*^ or record^*^ or data^*^ or manag^*^ or self-manag^*^ or counsel^*^ or therap^*^ or alliance or coordinat^*^ or co-ordinat^*^ or communicat^*^ or cognitive or interview^*^ or psychosocial or psycho-social or multicomponent or multi-component or support^*^ or tailor^*^ or coach^*^ or diary or diaries or behavioral or behavioural or family^*^ or families^*^ or peer^*^ or communit^*^ or decision^*^ or educat^*^ or psychoeducation^*^ or psychoeducation^*^ or train^*^ or incentiv^*^ or facilitat^*^ or “supervised treatment in out-patients for schizophren^*^” or STOPS or ((reduc^*^ or remov^*^) adj2 barrier^*^) or “30-day Adherence Question” or “5-item Questionnaire” or “Adherence Attitude Inventory” or “Adherence Question” or “Adherence Questionnaire” or “Adherence Self-Report Questionnaire” or ASRQ or “Adherence Starts with Knowledge-12” or ASK-12 or “Adherence Starts with Knowledge-20” or ASK-20 or “Adherence to Refills and Medications Scale” or “Adherence Visual Analogue Scale” or “Beliefs about Medicines Questionnaire” or “Beliefs and Behaviour Questionnaire” or “Beliefs and Behavior Questionnaire” or “Brief Adherence Rating Scale” or “Brief Evaluation of Medication Influences and Beliefs” or BEMIB or “Brief Medication Questionnaire” or “Brooks Medication Adherence Scale” or BMAS or “Centre for Adherence Support Evaluation” or “CASE Adherence Index” or “CASE Index” or “Compliance Questionnaire Rheumatology” or “Drug Attitude Inventory” or “Hill-Bone Compliance Scale” or “Immunosuppressant Therapy Adherence Scale” or ITAS or “Maastricht Utrecht Adherence in Hypertension Questionnaire” or MUAH or “Medication Adherence Assessment Tool” or MAAT or “Medication Adherence Questionnaire” or MAQ or “Medication Adherence Reasons Scale” or “Medication Adherence Report Scale^*^” or “Medication Adherence Self-Efficacy Scale” or MASES or “Medication Adherence Self-Efficacy Scale Revised” or MASES-R or “Morisky Medication Adherence Scale” or MMAS or “Modified Morisky Scale” or MMS or Morisky-8 or MMS-8 or Morisky-4 or MMS-4 or “Osteoporosis-Specific Morisky Medication Adherence Scale” or OS-MMAS or “Reported Adherence to Medicine Scale” or “Self-Reported Adherence Questionnaire” or SERAD or “Simplified Medication Adherence Questionnaire” or SMAQ or “Stages of Change for Adherence” or SOCA or “The Patterns of Asthma Medication Use Questionnaire” or “The Self-Efficacy for Appropriate Medication Use Scale”).ti,ab. | 3621995
22 | or/12-21 | 3623396
23 | and/1,11,22 | 3802
24 | limit 23 to animal | 38
25 | limit 24 to human | 14
26 | 24 not 25 | 24
27 | 23 not 26 | 3778
28 | limit 27 to (childhood <birth to 12 years> or adolescence <13 to 17 years>) | 246
29 | limit 28 to adulthood <18+ years> | 176
30 | 28 not 29 | 70
31 | 27 not 30 | 3708
32 | limit 31 to ((“0200 clinical case study” or 1400 nonclinical case study) and (chapter or “column/opinion” or “comment/reply” or editorial or encyclopedia entry or letter or obituary or poetry or publication information or reprint or review-book or review-media or review-software & other)) | 84
33 | 31 not 32 | 3624
34 | limit 33 to english language | 3270

EMBASE (Elsevier)

http://embase.com

Searched Date: January 29, 2015

Set | Search Strategy | Results
#50 | #49 AND [english]/lim | 3,004 (http://www.embase.com/search/results?viewsearch=50)
#49 | #48 NOT ‘case report’/de | 3,508 (http://www.embase.com/search/results?viewsearch=49)
#48 | #47 NOT ([editorial]/lim OR [letter]/lim) | 3,773 (http://www.embase.com/search/results?viewsearch=48)
#47 | #44 NOT #46 | 3,884 (http://www.embase.com/search/results?viewsearch=47)
#46 | #44 AND ([newborn]/lim OR [infant]/lim OR [child]/lim OR [preschool]/lim OR [school]/lim OR [adolescent]/lim) NOT ([young adult]/lim OR [adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) | 113 (http://www.embase.com/search/results?viewsearch=46)
#44 | #42 NOT #43 | 3,997 (http://www.embase.com/search/results?viewsearch=44)
#43 | #42 AND [animals]/lim NOT [humans]/lim | 13 (http://www.embase.com/search/results?viewsearch=43)
#42 | #41 NOT [medline]/lim | 4,010 (http://www.embase.com/search/results?viewsearch=42)
#41 | #6 AND #16 AND #40 | 9,802
#40 | #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 | 15,867,816 (http://www.embase.com/search/results?viewsearch=40)
#39 | intervention:ab,ti OR interventions:ab,ti OR program^*^:ab,ti OR reduce:ab,ti OR reduction:ab,ti OR ‘patient-level’:ab,ti OR ‘patient-levels’:ab,ti OR ‘system-level’:ab,ti OR ‘system-levels’:ab,ti OR ‘policy-level’:ab,ti OR ‘policy-levels’:ab,ti OR provider^*^:ab,ti OR strateg^*^:ab,ti OR enhanc^*^:ab,ti OR improv^*^:ab,ti OR increas^*^:ab,ti OR device^*^:ab,ti OR pill^*^:ab,ti OR packag^*^:ab,ti OR policy:ab,ti OR policies:ab,ti OR benefit^*^:ab,ti OR insurance:ab,ti OR insured:ab,ti OR contain^*^:ab,ti OR ‘co-pay’:ab,ti OR ‘co-pays’:ab,ti OR copay^*^:ab,ti OR cost^*^:ab,ti OR pharmacy^*^:ab,ti OR pharmacies^*^:ab,ti OR pharmacist^*^:ab,ti OR pharmacologist^*^:ab,ti OR remind^*^:ab,ti OR refill^*^:ab,ti OR ‘re-fill’:ab,ti OR ‘re-fills’:ab,ti OR inject^*^:ab,ti OR depot^*^:ab,ti OR lai:ab,ti OR dosing:ab,ti OR tele^*^:ab,ti OR email^*^:ab,ti OR text^*^:ab,ti OR virtual^*^:ab,ti OR computer^*^:ab,ti OR electronic^*^:ab,ti OR internet:ab,ti OR ehealth:ab,ti OR online:ab,ti OR interactive^*^:ab,ti OR interdisciplinary:ab,ti OR ‘inter-disciplinary’:ab,ti OR technolog^*^:ab,ti OR monitor^*^:ab,ti OR record^*^:ab,ti OR data^*^:ab,ti OR manag^*^:ab,ti OR ‘self-management’:ab,ti OR ‘self-managing’:ab,ti OR counsel^*^:ab,ti OR therap^*^:ab,ti OR alliance:ab,ti OR coordinat^*^:ab,ti OR ‘co-ordinated’:ab,ti OR ‘co-ordination’:ab,ti OR communicat^*^:ab,ti OR cognitive:ab,ti OR interview^*^:ab,ti OR psychosocial:ab,ti OR ‘psycho-social’:ab,ti OR multicomponent:ab,ti OR ‘multicomponent’:ab,ti OR support^*^:ab,ti OR tailor^*^:ab,ti OR coach^*^:ab,ti OR diary:ab,ti OR diaries:ab,ti OR behavioral:ab,ti OR behavioural:ab,ti OR family^*^:ab,ti OR families^*^:ab,ti OR peer^*^:ab,ti OR communit^*^:ab,ti OR decision^*^:ab,ti OR educat^*^:ab,ti OR psychoeducation^*^:ab,ti OR ‘psychoeducation’:ab,ti OR ‘psychoeducational’:ab,ti OR train^*^:ab,ti OR incentiv^*^:ab,ti OR facilitat^*^:ab,ti OR ‘supervised treatment in outpatients for schizophrenia’:ab,ti OR stops:ab,ti OR barrier^*^:ab,ti OR ‘30-day adherence question’:ab,ti OR ‘5-item questionnaire’:ab,ti OR ‘adherence attitude inventory’:ab,ti OR ‘adherence question’:ab,ti OR ‘adherence questionnaire’:ab,ti OR ‘adherence self-report questionnaire’:ab,ti OR asrq:ab,ti OR ‘adherence starts with knowledge-12’:ab,ti OR ‘ask 12’:ab,ti OR ‘adherence starts with knowledge-20’:ab,ti OR ‘ask 20’:ab,ti OR ‘adherence to refills and medications scale’:ab,ti OR ‘adherence visual analogue scale’:ab,ti OR ‘beliefs about medicines questionnaire’:ab,ti OR ‘beliefs and behaviour questionnaire’:ab,ti OR ‘beliefs and behavior questionnaire’:ab,ti OR ‘brief adherence rating scale’:ab,ti OR ‘brief evaluation of medication influences and beliefs’:ab,ti OR bemib:ab,ti OR ‘brief medication questionnaire’:ab,ti OR ‘brooks medication adherence scale’:ab,ti OR bmas:ab,ti OR ‘centre for adherence support evaluation’:ab,ti OR ‘case adherence index’:ab,ti OR ‘case index’:ab,ti OR ‘compliance questionnaire rheumatology’:ab,ti OR ‘drug attitude inventory’:ab,ti OR ‘hillbone compliance scale’:ab,ti OR ‘immunosuppressant therapy adherence scale’:ab,ti OR itas:ab,ti OR ‘maastricht utrecht adherence in hypertension questionnaire’:ab,ti OR muah:ab,ti OR ‘medication adherence assessment tool’:ab,ti OR maat:ab,ti OR ‘medication adherence questionnaire’:ab,ti OR maq:ab,ti OR ‘medication adherence reasons scale’:ab,ti OR ‘medication adherence report scale’:ab,ti OR ‘medication adherence self-efficacy scale’:ab,ti OR mases:ab,ti OR ‘medication adherence self-efficacy scale revised’:ab,ti OR ‘mases r’:ab,ti OR ‘morisky medication adherence scale’:ab,ti OR mmas:ab,ti OR ‘modified morisky scale’:ab,ti OR mms:ab,ti OR ‘morisky 8’:ab,ti OR ‘mms 8’:ab,ti OR ‘morisky 4’:ab,ti OR ‘mms 4’:ab,ti OR ‘osteoporosis-specific morisky medication adherence scale’:ab,ti OR ‘os mmas’:ab,ti OR ‘reported adherence to medicine scale’:ab,ti OR ‘self-reported adherence questionnaire’:ab,ti OR serad:ab,ti OR ‘simplified medication adherence questionnaire’:ab,ti OR smaq:ab,ti OR ‘stages of change for adherence’:ab,ti OR soca:ab,ti OR ‘the patterns of asthma medication use questionnaire’:ab,ti OR ‘the self-efficacy for appropriate medication use scale’:ab,ti | 14,570,620 (http://www.embase.com/search/results?viewsearch=39)
#38 | ‘hospital pharmacy’/de | 12,567
#37 | ‘disease management’/exp | 1,803,597 (http://www.embase.com/search/results?viewsearch=37)
#36 | ‘program development’/de | 17,753
#35 | ‘socioeconomics’/exp | 181,927
#34 | ‘health services research’/de | 27,052
#33 | ‘drug packaging’/de | 7,798
#32 | ‘drug cost’/de | 59,763
#31 | ‘polypharmacy’/de | 7,731
#30 | ‘prescription drug’/de | 4,089
#29 | ‘primary health care’/exp | 111,492
#28 | ‘health maintenance organization’/de | 17,030
#27 | ‘health insurance’/exp | 190,051
#25 | ‘pharmacy’/de | 56,409
#24 | ‘health care policy’/de | 146,123
#23 | ‘health care delivery’/exp | 2,034,947
#22 | ‘medicaid’/exp | 29,190
#21 | ‘medicare’/exp | 53,706
#20 | ‘insurance’/exp | 235,070
#19 | ‘health care planning’/de | 79,255
#18 | ‘policy’/de | 76,327
#17 | ‘management’/exp | 731,630 (http://www.embase.com/search/results?viewsearch=17)
#16 | #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 | 346,198
#15 | psychotic:ab,ti OR schizotyp^*^:ab,ti OR schizophren^*^:ab,ti OR schizoid^*^:ab,ti OR schizoaffective:ab,ti OR bipolar:ab,ti OR mania^*^:ab,ti OR hypomania^*^:ab,ti OR ‘hypo-mania’:ab,ti OR ‘hypo-manias’:ab,ti OR manic:ab,ti OR cyclothymic^*^:ab,ti OR ptsd^*^:ab,ti OR ‘post-traumatic stress’:ab,ti OR ‘posttraumatic stress’:ab,ti OR ‘severe mental illness’:ab,ti OR ‘severely mentally ill’:ab,ti OR ‘serious mental illness’:ab,ti OR ‘seriously mentally ill’:ab,ti OR ‘chronic mental illness’:ab,ti OR ‘chronically mentally ill’:ab,ti OR ‘persistent mental illness’:ab,ti OR ‘persistently mentally ill’:ab,ti | 232,690
#14 | ‘acute stress disorder’/de | 980
#13 | ‘posttraumatic stress disorder’/de | 36,791
#12 | ‘bipolar disorder’/exp | 50,154
#11 | ‘schizotypal personality disorder’/de | 1,908
#10 | ‘schizoidism’/de | 2,514
#9 | ‘shared psychotic disorder’/exp | 219
#8 | ‘schizophrenia’/exp | 145,829
#7 | ‘psychosis’/exp | 224,632
#6 | #1 OR #2 OR #3 OR #4 OR #5 | 187,065
#5 | ((medication^*^ OR pharmaceutical^*^ OR drug^*^ OR pharmacotherap^*^ OR regimen^*^ OR therap^*^ OR treat^*^ OR prophylaxis OR psychotropic OR psychopharmac^*^ OR pharmacolog^*^ OR antipsychot^*^ OR ‘anti psychotic’ OR ‘anti psychotics’ OR neuroleptic^*^ OR ‘mood stabilizer’ OR ‘mood stabilizers’ OR antiepileptic^*^ OR ‘anti epileptic’ OR ‘anti epileptics’ OR anticonvulsant^*^ OR ‘anti convulsant’ OR ‘anti convulsants’ OR poor^*^ OR patient^*^ OR client^*^ OR refus^*^) NEAR/3 (adheren^*^ OR ‘non adherent’ OR ‘non adherence’ OR nonadheren^*^ OR complian^*^ OR ‘non compliant’ OR ‘non compliance’ OR noncomplian^*^ OR persistent OR persistence OR ‘non persistent’ OR ‘non persistence’ OR nonpersistence OR nonpersistent OR reconciliat^*^)):ab,ti | 108,783 (http://www.embase.com/search/results?viewsearch=5)
#4 | ‘medication compliance’/de | 12,550
#3 | ‘medication compliance’/de | 3,630
#2 | ‘patient compliacne’/de | 99,293
#1 | ‘medication compliance’/de | 6,242

Cochrane Library (Ovid EBM Reviews)

- Cochrane Central Register of Controlled Trials December 2014
- Cochrane Database of Systematic Reviews 2005 to December 2014
- Database of Abstracts of Reviews of Effects 4th Quarter 2014
- Health Technology Assessment 4th Quarter 2014
- NHS Economic Evaluation Database 4th Quarter 2014

Date Searched: January 29, 2015

1 | (((medication^*^ or pharmaceutical^*^ or drug^*^ or pharmacotherap^*^ or regimen^*^ or therap^*^ or treat^*^ or prophylaxis or psychotropic or psychopharmac^*^ or pharmacolog^*^ or antipsychot^*^ or anti-psychot^*^ or neuroleptic^*^ or mood stabilizer^*^ or antiepileptic^*^ or anti-epileptic^*^ or anticonvulsant^*^ or anti-convulsant^*^ or poor^*^ or patient^*^ or client^*^ or refus^*^) adj3 (adheren^*^ or non-adheren^*^ or nonadheren^*^ or complian^*^ or non-complian^*^ or noncomplian^*^ or persist^*^ or non-persist^*^ or nonpersist^*^ or reconciliat^*^)) or medication therapy management).ti,ab. | 14975
2 | (psychotic or schizotyp^*^ or schizophren^*^ or schizoid^*^ or schizoaffective or bipolar or mania^*^ or hypomania^*^ or hypo-mania^*^ or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or ((severe^*^ or serious^*^ or chronic^*^ or persistent^*^) adj mental^*^ ill^*^)).ti,ab. | 15934
3 | (intervention or interventions or program^*^ or reduce or reduction or patient-level^*^ or system-level^*^ or policy-level^*^ or provider^*^ or strateg^*^ or enhanc^*^ or improv^*^ or increas^*^ or device^*^ or pill^*^ or packag^*^ or policy or policies or benefit^*^ or insurance or insured or contain^*^ or co-pay^*^ or copay^*^ or cost^*^ or pharmacy^*^ or pharmacies^*^ or pharmacist^*^ or pharmacologist^*^ or remind^*^ or refill^*^ or re-fill^*^ or inject^*^ or depot^*^ or LAI or dosing or tele^*^ or email^*^ or text^*^ or virtual^*^ or computer^*^ or electronic^*^ or internet or ehealth or online or interactive^*^ or interdisciplinary or inter-disciplinary or technolog^*^ or monitor^*^ or record^*^ or data^*^ or manag^*^ or self-manag^*^ or counsel^*^ or therap^*^ or alliance or coordinat^*^ or co-ordinat^*^ or communicat^*^ or cognitive or interview^*^ or psychosocial or psycho-social or multicomponent or multi-component or support^*^ or tailor^*^ or coach^*^ or diary or diaries or behavioral or behavioural or family^*^ or families^*^ or peer^*^ or communit^*^ or decision^*^ or educat^*^ or psychoeducation^*^ or psychoeducation^*^ or train^*^ or incentiv^*^ or facilitat^*^ or supervised treatment in out-patients for schizophren^*^ or STOPS or (((reduc^*^ or remov^*^) adj2 barrier^*^) or “30-day Adherence Question” or “5-item Questionnaire” or “Adherence Attitude Inventory” or “Adherence Question” or “Adherence Questionnaire” or “Adherence Self-Report Questionnaire” or ASRQ or “Adherence Starts with Knowledge-12” or ASK-12 or “Adherence Starts with Knowledge-20” or ASK-20 or “Adherence to Refills and Medications Scale” or “Adherence Visual Analogue Scale” or “Beliefs about Medicines Questionnaire” or “Beliefs and Behaviour Questionnaire” or “Beliefs and Behavior Questionnaire” or “Brief Adherence Rating Scale” or “Brief Evaluation of Medication Influences and Beliefs” or BEMIB or “Brief Medication Questionnaire” or “Brooks Medication Adherence Scale” or BMAS or “Centre for Adherence Support Evaluation” or “CASE Adherence Index” or “CASE Index” or “Compliance Questionnaire Rheumatology” or “Drug Attitude Inventory” or “Hill-Bone Compliance Scale” or “Immunosuppressant Therapy Adherence Scale” or ITAS or “Maastricht Utrecht Adherence in Hypertension Questionnaire” or MUAH or “Medication Adherence Assessment Tool” or MAAT or “Medication Adherence Questionnaire” or MAQ or “Medication Adherence Reasons Scale” or “Medication Adherence Report Scale^*^” or “Medication Adherence Self-Efficacy Scale” or MASES or “Medication Adherence Self-Efficacy Scale Revised” or MASES-R or “Morisky Medication Adherence Scale” or MMAS or “Modified Morisky Scale” or MMS or Morisky-8 or MMS-8 or Morisky-4 or MMS-4 or “Osteoporosis-Specific Morisky Medication Adherence Scale” or OS-MMAS or “Reported Adherence to Medicine Scale” or “Self-Reported Adherence Questionnaire” or SERAD or “Simplified Medication Adherence Questionnaire” or SMAQ or “Stages of Change for Adherence” or SOCA or “The Patterns of Asthma Medication Use Questionnaire” or “The Self-Efficacy for Appropriate Medication Use Scale”)).ti,ab. | 591600
4 | and/1-3 | 700
5 | limit 4 to medline records [Limit not valid in CDSR,DARE,CLHTA,CLEED; records were retained] | 419
6 | 4 not 5 | 281
7 | limit 6 to english language [Limit not valid in CDSR,DARE; records were retained] | 155

EBSCOHost CINAHL Plus with Full Text

Date Searched: January 29, 2015

Search ID# | Search Terms | Search Options | Actions
S40 | S7 AND S16 AND S39 | Limiters - English Language; Age Groups: Adult: 19-44 years, Middle Aged: 45-64 years, Aged: 65+ years, Aged, 80 and over; Exclude MEDLINE records | 152
S39 | S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 | | 2,861,309
S38 | (AB intervention or interventions or program^*^ or reduce or reduction or patient-level^*^ or system-level^*^ or policy-level^*^ or provider^*^ or strateg^*^ or enhanc^*^ or improv^*^ or increas^*^ or device^*^ or pill^*^ or packag^*^ or policy or policies or benefit^*^ or insurance or insured or contain^*^ or co-pay^*^ or copay^*^ or cost^*^ or pharmacy^*^ or pharmacies^*^ or pharmacist^*^ or pharmacologist^*^ or remind^*^ or refill^*^ or re-fill^*^ or inject^*^ or depot^*^ or LAI or dosing or tele^*^ or email^*^ or text^*^ or virtual^*^ or computer^*^ or electronic^*^ or internet or ehealth or online or interactive^*^ or interdisciplinary or inter-disciplinary or technolog^*^ or monitor^*^ or record^*^ or data^*^ or manag^*^ or self-manag^*^ or counsel^*^ or therap^*^ or alliance or coordinat^*^ or co-ordinat^*^ or communicat^*^ or cognitive or interview^*^ or psychosocial or psycho-social or multicomponent or multi-component or support^*^ or tailor^*^ or coach^*^ or diary or diaries or behavioral or behavioural or family^*^ or families^*^ or peer^*^ or communit^*^ or decision^*^ or educat^*^ or psychoeducation^*^ or psychoeducation^*^ or train^*^ or incentiv^*^ or facilitat^*^ or “supervised treatment in out-patients for schizophren^*^” or STOPS or ((reduc^*^ or remov^*^) adj2 barrier^*^) or “30-day Adherence Question” or “5-item Questionnaire” or “Adherence Attitude Inventory” or “Adherence Question” or “Adherence Questionnaire” or “Adherence Self-Report Questionnaire” or ASRQ or “Adherence Starts with Knowledge-12” or ASK-12 or “Adherence Starts with Knowledge-20” or ASK-20 or “Adherence to Refills and Medications Scale” or “Adherence Visual Analogue Scale” or “Beliefs about Medicines Questionnaire” or “Beliefs and Behaviour Questionnaire” or “Beliefs and Behavior Questionnaire” or “Brief Adherence Rating Scale” or “Brief Evaluation of Medication Influences and Beliefs” or BEMIB or “Brief Medication Questionnaire” or “Brooks Medication Adherence Scale” or BMAS or “Centre for Adherence Support Evaluation” or “CASE Adherence Index” or “CASE Index” or “Compliance Questionnaire Rheumatology” or “Drug Attitude Inventory” or “Hill-Bone Compliance Scale” or “Immunosuppressant Therapy Adherence Scale” or ITAS or “Maastricht Utrecht Adherence in Hypertension Questionnaire” or MUAH or “Medication Adherence Assessment Tool” or MAAT or “Medication Adherence Questionnaire” or MAQ or “Medication Adherence Reasons Scale” or “Medication Adherence Report Scale^*^” or “Medication Adherence Self-Efficacy Scale” or MASES or “Medication Adherence Self-Efficacy Scale Revised” or MASES-R or “Morisky Medication Adherence Scale” or MMAS or “Modified Morisky Scale” or MMS or Morisky-8 or MMS-8 or Morisky-4 or MMS-4 or “Osteoporosis-Specific Morisky Medication Adherence Scale” or OS-MMAS or “Reported Adherence to Medicine Scale” or “Self-Reported Adherence Questionnaire” or SERAD or “Simplified Medication Adherence Questionnaire” or SMAQ or “Stages of Change for Adherence” or SOCA or “The Patterns of Asthma Medication Use Questionnaire” or “The Self-Efficacy for Appropriate Medication Use Scale” | | 2,838,440
S37 | (TI intervention or interventions or program^*^ or reduce or reduction or patient-level^*^ or system-level^*^ or policy-level^*^ or provider^*^ or strateg^*^ or enhanc^*^ or improv^*^ or increas^*^ or device^*^ or pill^*^ or packag^*^ or policy or policies or benefit^*^ or insurance or insured or contain^*^ or co-pay^*^ or copay^*^ or cost^*^ or pharmacy^*^ or pharmacies^*^ or pharmacist^*^ or pharmacologist^*^ or remind^*^ or refill^*^ or re-fill^*^ or inject^*^ or depot^*^ or LAI or dosing or tele^*^ or email^*^ or text^*^ or virtual^*^ or computer^*^ or electronic^*^ or internet or ehealth or online or interactive^*^ or interdisciplinary or inter-disciplinary or technolog^*^ or monitor^*^ or record^*^ or data^*^ or manag^*^ or self-manag^*^ or counsel^*^ or therap^*^ or alliance or coordinat^*^ or co-ordinat^*^ or communicat^*^ or cognitive or interview^*^ or psychosocial or psycho-social or multicomponent or multi-component or support^*^ or tailor^*^ or coach^*^ or diary or diaries or behavioral or behavioural or family^*^ or families^*^ or peer^*^ or communit^*^ or decision^*^ or educat^*^ or psychoeducation^*^ or psychoeducation^*^ or train^*^ or incentiv^*^ or facilitat^*^ or “supervised treatment in out-patients for schizophren^*^” or STOPS or ((reduc^*^ or remov^*^) adj2 barrier^*^) or “30-day Adherence Question” or “5-item Questionnaire” or “Adherence Attitude Inventory” or “Adherence Question” or “Adherence Questionnaire” or “Adherence Self-Report Questionnaire” or ASRQ or “Adherence Starts with Knowledge-12” or ASK-12 or “Adherence Starts with Knowledge-20” or ASK-20 or “Adherence to Refills and Medications Scale” or “Adherence Visual Analogue Scale” or “Beliefs about Medicines Questionnaire” or “Beliefs and Behaviour Questionnaire” or “Beliefs and Behavior Questionnaire” or “Brief Adherence Rating Scale” or “Brief Evaluation of Medication Influences and Beliefs” or BEMIB or “Brief Medication Questionnaire” or “Brooks Medication Adherence Scale” or BMAS or “Centre for Adherence Support Evaluation” or “CASE Adherence Index” or “CASE Index” or “Compliance Questionnaire Rheumatology” or “Drug Attitude Inventory” or “Hill-Bone Compliance Scale” or “Immunosuppressant Therapy Adherence Scale” or ITAS or “Maastricht Utrecht Adherence in Hypertension Questionnaire” or MUAH or “Medication Adherence Assessment Tool” or MAAT or “Medication Adherence Questionnaire” or MAQ or “Medication Adherence Reasons Scale” or “Medication Adherence Report Scale^*^” or “Medication Adherence Self-Efficacy Scale” or MASES or “Medication Adherence Self-Efficacy Scale Revised” or MASES-R or “Morisky Medication Adherence Scale” or MMAS or “Modified Morisky Scale” or MMS or Morisky-8 or MMS-8 or Morisky-4 or MMS-4 or “Osteoporosis-Specific Morisky Medication Adherence Scale” or OS-MMAS or “Reported Adherence to Medicine Scale” or “Self-Reported Adherence Questionnaire” or SERAD or “Simplified Medication Adherence Questionnaire” or SMAQ or “Stages of Change for Adherence” or SOCA or “The Patterns of Asthma Medication Use Questionnaire” or “The Self-Efficacy for Appropriate Medication Use Scale”) | | 2,839,476
S36 | (MH “Drug Administration Schedule”) | | 9,991
S35 | (MH “Pharmacy Service”) | | 4,334
S34 | (MH “Disease Management”) | | 9,150
S33 | (MH “Program Development”) | | 16,877
S32 | (MH “Health Services Research”) | | 9,793
S31 | (MH “Drug Packaging”) | | 869
S30 | (MH “Polypharmacy”) | | 2,179
S29 | (MH “Drugs, Prescription”) | | 13,214
S28 | (MH “Primary Health Care/AM/EC”) | | 3,452
S27 | (MH “Health Maintenance Organizations/AM”) | | 413
S26 | (MH “Managed Care Programs”) | | 10,452
S25 | (MH “Insurance, Pharmaceutical Services”) | | 1,396
S24 | (MH “Pharmacy Service”) | | 4,334
S23 | (MH “Formularies”) | | 1,426
S22 | (MH “Health Policy”) | | 33,206
S21 | (MH “Health Services Accessibility”) | | 51,804
S20 | (MH “Medicaid”) | | 12,256
S19 | (MH “Medicare”) | | 27,432
S18 | (MH “Public Policy”) | | 14,087
S17 | (MH “Policy Making”) | | 6,812
S16 | S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 | | 50,411
S15 | (AB psychotic or schizotyp^*^ or schizophren^*^ or schizoid^*^ or schizoaffective or bipolar or mania^*^ or hypomania^*^ or hypo-mania^*^ or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or ((severe^*^ or serious^*^ or chronic^*^ or persistent^*^) N1 mental^*^ ill^*^)) | | 39,775
S14 | (TI psychotic or schizotyp^*^ or schizophren^*^ or schizoid^*^ or schizoaffective or bipolar or mania^*^ or hypomania^*^ or hypo-mania^*^ or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or ((severe^*^ or serious^*^ or chronic^*^ or persistent^*^) N1 mental^*^ ill^*^)) | | 39,263
S13 | (MH “Stress Disorders, Post-Traumatic”) | | 12,867
S12 | (MH “Bipolar Disorder”) OR (MH “Cyclothymic Disorder”) | | 7,216
S11 | (MH “Schizotypal Personality Disorder”) | | 154
S10 | (MH “Catatonia”) | | 259
S9 | (MH “Schizophrenia”) | | 15,895
S8 | (MH “Psychotic Disorders”) OR (MH “Affective Disorders, Psychotic”) OR (MH “Organic Mental Disorders, Psychotic”) OR (MH “Postpartum Psychosis”) OR (MH “Paranoid Disorders”) | | 7,494
S7 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 | | 45,088
S6 | ((AB medication^*^ or pharmaceutical^*^ or drug^*^ or pharmacotherap^*^ or regimen^*^ or therap^*^ or treat^*^ or prophylaxis or psychotropic or psychopharmac^*^ or pharmacolog^*^ or antipsychot^*^ or anti-psychot^*^ or neuroleptic^*^ or mood stabilizer^*^ or antiepileptic^*^ or anti-epileptic^*^ or anticonvulsant^*^ or anti-convulsant^*^ or poor^*^ or patient^*^ or client^*^ or refus^*^) N3 (AB adheren^*^ or non-adheren^*^ or nonadheren^*^ or complian^*^ or non-complian^*^ or noncomplian^*^ or persist^*^ or non-persist^*^ or nonpersist^*^ or reconciliat^*^)) or (AB medication therapy management) | | 32,326
S5 | ((TI medication^*^ or pharmaceutical^*^ or drug^*^ or pharmacotherap^*^ or regimen^*^ or therap^*^ or treat^*^ or prophylaxis or psychotropic or psychopharmac^*^ or pharmacolog^*^ or antipsychot^*^ or anti-psychot^*^ or neuroleptic^*^ or mood stabilizer^*^ or antiepileptic^*^ or anti-epileptic^*^ or anticonvulsant^*^ or anti-convulsant^*^ or poor^*^ or patient^*^ or client^*^ or refus^*^) N3 (TI adheren^*^ or non-adheren^*^ or nonadheren^*^ or complian^*^ or non-complian^*^ or noncomplian^*^ or persist^*^ or non-persist^*^ or nonpersist^*^ or reconciliat^*^)) or (TI medication therapy management) | | 33,726
S4 | (MH “Treatment Refusal”) | | 3,723
S3 | (MH “Medication Reconciliation”) | | 763
S2 | (MH “Patient Compliance”) | | 20,473
S1 | (MH “Medication Compliance”) | | 10,944

ClinicalTrials.gov

Searched Date: January 29, 2013

Search Strategy-Advanced Search Interface | Result
SEARCH TERMS: adherence OR adherent OR non-adherence OR non-adherent OR nonadherence OR nonadherent OR compliance OR compliant OR non-compliant OR noncompliant OR non-compliance OR noncompliance OR persistence OR non-persistence OR nonpersistence OR reconciliation RECRUITMENT: Closed Studies STUDY RESULTS: All Studies STUDY TYPE: Interventional Studies CONDITIONS: psychosis OR psychotic OR schizotypal OR schizophrenia OR schizophreniform OR schizoidal OR schizoaffective OR bipolar OR mania OR manias OR hypomania OR hypo-mania OR cyclothymic OR PTSD OR post-traumatic stress OR posttraumatic stress | 439

WHO ICTRP (World Health Organization, International Clinical Trials Registry Platform)

http://apps.who.int/trialsearch/AdvSearch.aspx

Searched Date: January 29, 2015

Search Strategy | Result
TITLE SEARCH: adherence OR adherent OR non-adherence OR non-adherent OR nonadherence OR nonadherent OR compliance OR compliant OR non-compliant OR noncompliant OR non-compliance OR noncompliance OR persistence OR non-persistence OR nonpersistence OR reconciliation AND CONDITION SEARCH: psychosis OR psychotic OR schizotypal OR schizophrenia OR schizophreniform OR schizoidal OR schizoaffective OR bipolar OR mania OR manias OR hypomania OR hypo-mania OR cyclothymic OR PTSD OR post-traumatic stress OR posttraumatic stress | 81 records for 79 trials found

ISRCTN Registry

http://www.isrctn.com/editAdvancedSearch

Searched Date: January 30, 2015

Search Strategy | Result
TEXT SEARCH: Adherence OR adherent OR non-adherence OR non-adherent OR nonadherence OR nonadherent OR compliance OR compliant OR non-compliance OR non-compliant OR noncompliance OR noncompliant OR persistence OR non-persistence OR nonpersistence or reconciliation or “medication therapy management” AND CONDITION SEARCH: psychotic OR psychosis OR schizotypal OR schizophrenia OR schizophrenic OR schizophreniform OR schizoid OR schizoaffective OR bipolar OR mania OR manias OR hypomania OR hypomanias OR hypo-mania OR hypo-manias OR manic OR cyclothymic OR PTSD OR post-traumatic stress OR posttraumatic stress OR severely mentally ill OR severe mental illness OR seriously mentally ill OR serious mental illness OR chronically mentally ill OR chronic mental illness OR persistently mentally ill OR persistent mental illness | 0

ProQuest Conference Papers Index

Searched Date: January 29, 2015

Search Strategy (Command Line Search) | Results
TI,AB(medication^*^ or pharmaceutical^*^ or drug^*^ or pharmacotherap^*^ or regimen^*^ or therap^*^ or treat^*^ or prophylaxis or psychotropic or psychopharmac^*^ or pharmacolog^*^ or antipsychot^*^ or anti-psychot^*^ or neuroleptic^*^ or mood stabilizer^*^ or antiepileptic^*^ or anti-epileptic^*^ or anticonvulsant^*^ or anti-convulsant^*^ or poor^*^ or patient^*^ or client^*^ or refus^*^) AND TI,AB(adheren^*^ or non-adheren^*^ or nonadheren^*^ or complian^*^ or non-complian^*^ or noncomplian^*^ or persist^*^ or non-persist^*^ or nonpersist^*^ or reconciliat^*^) AND TI,AB(psychotic or schizotyp^*^ or schizophren^*^ or schizoid^*^ or schizoaffective or bipolar or mania^*^ or hypomania^*^ or hypo-mania^*^ or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or severe^*^ mental^*^ ill^*^ or serious^*^ mental^*^ ill^*^ or chronic^*^ mental^*^ ill^*^ or persistent^*^ mental^*^ ill^*^) AND TI,AB(intervention or interventions or program^*^ or reduce or reduction or patient-level^*^ or system-level^*^ or policy-level^*^ or provider^*^ or strateg^*^ or enhanc^*^ or improv^*^ or increas^*^ or device^*^ or pill^*^ or packag^*^ or policy or policies or benefit^*^ or insurance or insured or contain^*^ or co-pay^*^ or copay^*^ or cost^*^ or pharmacy^*^ or pharmacies^*^ or pharmacist^*^ or pharmacologist^*^ or remind^*^ or refill^*^ or re-fill^*^ or inject^*^ or depot^*^ or LAI or dosing or tele^*^ or email^*^ or text^*^ or virtual^*^ or computer^*^ or electronic^*^ or internet or ehealth or online or interactive^*^ or interdisciplinary or inter-disciplinary or technolog^*^ or monitor^*^ or record^*^ or data^*^ or manag^*^ or self-manag^*^ or counsel^*^ or therap^*^ or alliance or coordinat^*^ or co-ordinat^*^ or communicat^*^ or cognitive or interview^*^ or psychosocial or psycho-social or multicomponent or multi-component or support^*^ or tailor^*^ or coach^*^ or diary or diaries or behavioral or behavioural or family^*^ or families^*^ or peer^*^ or communit^*^ or decision^*^ or educat^*^ or psychoeducation^*^ or psychoeducation^*^ or train^*^ or incentiv^*^ or facilitat^*^ or supervised treatment in out-patients for schizophren^*^ or STOPS or reduc^*^ N/2 barrier^*^ or remov^*^ n/2 barrier^*^ or “30-day Adherence Question” or “5-item Questionnaire” or “Adherence Attitude Inventory” or “Adherence Question” or “Adherence Questionnaire” or “Adherence Self-Report Questionnaire” or ASRQ or “Adherence Starts with Knowledge-12” or ASK-12 or “Adherence Starts with Knowledge-20” or ASK-20 or “Adherence to Refills and Medications Scale” or “Adherence Visual Analogue Scale” or “Beliefs about Medicines Questionnaire” or “Beliefs and Behaviour Questionnaire” or “Beliefs and Behavior Questionnaire” or “Brief Adherence Rating Scale” or “Brief Evaluation of Medication Influences and Beliefs” or BEMIB or “Brief Medication Questionnaire” or “Brooks Medication Adherence Scale” or BMAS or “Centre for Adherence Support Evaluation” or “CASE Adherence Index” or “CASE Index” or “Compliance Questionnaire Rheumatology” or “Drug Attitude Inventory” or “Hill-Bone Compliance Scale” or “Immunosuppressant Therapy Adherence Scale” or ITAS or “Maastricht Utrecht Adherence in Hypertension Questionnaire” or MUAH or “Medication Adherence Assessment Tool” or MAAT or “Medication Adherence Questionnaire” or MAQ or “Medication Adherence Reasons Scale” or “Medication Adherence Report Scale^*^” or “Medication Adherence Self-Efficacy Scale” or MASES or “Medication Adherence Self-Efficacy Scale Revised” or MASES-R or “Morisky Medication Adherence Scale” or MMAS or “Modified Morisky Scale” or MMS or Morisky-8 or MMS-8 or Morisky-4 or MMS-4 or “Osteoporosis-Specific Morisky Medication Adherence Scale” or OS-MMAS or “Reported Adherence to Medicine Scale” or “Self-Reported Adherence Questionnaire” or SERAD or “Simplified Medication Adherence Questionnaire” or SMAQ or “Stages of Change for Adherence” or SOCA or “The Patterns of Asthma Medication Use Questionnaire” or “The Self-Efficacy for Appropriate Medication Use Scale”) | 36

ProQuest Dissertations & Theses Global

Searched Date: January 29, 2015

TI,AB(medication^*^ or pharmaceutical^*^ or drug^*^ or pharmacotherap^*^ or regimen^*^ or therap^*^ or treat^*^ or prophylaxis or psychotropic or psychopharmac^*^ or pharmacolog^*^ or antipsychot^*^ or anti-psychot^*^ or neuroleptic^*^ or mood stabilizer^*^ or antiepileptic^*^ or anti-epileptic^*^ or anticonvulsant^*^ or anti-convulsant^*^ or poor^*^ or patient^*^ or client^*^ or refus^*^) AND TI,AB(adheren^*^ or non-adheren^*^ or nonadheren^*^ or complian^*^ or non-complian^*^ or noncomplian^*^ or persist^*^ or non-persist^*^ or nonpersist^*^ or reconciliat^*^) AND TI,AB(psychotic or schizotyp^*^ or schizophren^*^ or schizoid^*^ or schizoaffective or bipolar or mania^*^ or hypomania^*^ or hypo-mania^*^ or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or severe^*^ mental^*^ ill^*^ or serious^*^ mental^*^ ill^*^ or chronic^*^ mental^*^ ill^*^ or persistent^*^ mental^*^ ill^*^) AND TI,AB(intervention or interventions or program^*^ or reduce or reduction or patient-level^*^ or system-level^*^ or policy-level^*^ or provider^*^ or strateg^*^ or enhanc^*^ or improv^*^ or increas^*^ or device^*^ or pill^*^ or packag^*^ or policy or policies or benefit^*^ or insurance or insured or contain^*^ or co-pay^*^ or copay^*^ or cost^*^ or pharmacy^*^ or pharmacies^*^ or pharmacist^*^ or pharmacologist^*^ or remind^*^ or refill^*^ or re-fill^*^ or inject^*^ or depot^*^ or LAI or dosing or tele^*^ or email^*^ or text^*^ or virtual^*^ or computer^*^ or electronic^*^ or internet or ehealth or online or interactive^*^ or interdisciplinary or inter-disciplinary or technolog^*^ or monitor^*^ or record^*^ or data^*^ or manag^*^ or self-manag^*^ or counsel^*^ or therap^*^ or alliance or coordinat^*^ or co-ordinat^*^ or communicat^*^ or cognitive or interview^*^ or psychosocial or psycho-social or multicomponent or multi-component or support^*^ or tailor^*^ or coach^*^ or diary or diaries or behavioral or behavioural or family^*^ or families^*^ or peer^*^ or communit^*^ or decision^*^ or educat^*^ or psychoeducation^*^ or psychoeducation^*^ or train^*^ or incentiv^*^ or facilitat^*^ or supervised treatment in out-patients for schizophren^*^ or STOPS or reduc^*^ N/2 barrier^*^ or remov^*^ n/2 barrier^*^ or “30-day Adherence Question” or “5-item Questionnaire” or “Adherence Attitude Inventory” or “Adherence Question” or “Adherence Questionnaire” or “Adherence Self-Report Questionnaire” or ASRQ or “Adherence Starts with Knowledge-12” or ASK-12 or “Adherence Starts with Knowledge-20” or ASK-20 or “Adherence to Refills and Medications Scale” or “Adherence Visual Analogue Scale” or “Beliefs about Medicines Questionnaire” or “Beliefs and Behaviour Questionnaire” or “Beliefs and Behavior Questionnaire” or “Brief Adherence Rating Scale” or “Brief Evaluation of Medication Influences and Beliefs” or BEMIB or “Brief Medication Questionnaire” or “Brooks Medication Adherence Scale” or BMAS or “Centre for Adherence Support Evaluation” or “CASE Adherence Index” or “CASE Index” or “Compliance Questionnaire Rheumatology” or “Drug Attitude Inventory” or “Hill-Bone Compliance Scale” or “Immunosuppressant Therapy Adherence Scale” or ITAS or “Maastricht Utrecht Adherence in Hypertension Questionnaire” or MUAH or “Medication Adherence Assessment Tool” or MAAT or “Medication Adherence Questionnaire” or MAQ or “Medication Adherence Reasons Scale” or “Medication Adherence Report Scale^*^” or “Medication Adherence Self-Efficacy Scale” or MASES or “Medication Adherence Self-Efficacy Scale Revised” or MASES-R or “Morisky Medication Adherence Scale” or MMAS or “Modified Morisky Scale” or MMS or Morisky-8 or MMS-8 or Morisky-4 or MMS-4 or “Osteoporosis-Specific Morisky Medication Adherence Scale” or OS-MMAS or “Reported Adherence to Medicine Scale” or “Self-Reported Adherence Questionnaire” or SERAD or “Simplified Medication Adherence Questionnaire” or SMAQ or “Stages of Change for Adherence” or SOCA or “The Patterns of Asthma Medication Use Questionnaire” or “The Self-Efficacy for Appropriate Medication Use Scale”)