# APPENDIX A TECHNICAL EXPERT PANEL

- Jennifer Bean, Pharm.D (VA)
  Clinical Pharmacy Specialist (Psychiatry and Pharmacotherapy), VA Tennessee Valley Healthcare System
- Joyce Cramer (former VA)
  Medical Research Consultant
  Associate Research Scientist in Psychiatry, Yale University Department of Psychiatry, retired
  West Haven VA Medical Center, retired
- Colin Depp, PhD (VA)
  Associate Professor of Psychiatry, University of California, San Diego
  Staff Psychologist, VA San Diego Health Care System
- Walid Gellad, MD, MPH (VA)
  Core Investigator, Center for Health Equity Research and Promotion
  Staff Physician, VA Pittsburgh Healthcare System
  Assistant Professor of Medicine, University of Pittsburgh School of Medicine
  Assistant Professor of Health Policy and Management, University of Pittsburgh Graduate School of Public Health
- Jennifer Houser, Pharm.D (VA)
  Clinical Pharmacy Specialist (Mental Health), William Jennings Bryan Dorn VA Medical Center
- Teresa Hudson, Pharm.D, PhD (VA)
  Associate Director, Division of Health Services Research, Psychiatric Research Institute, University of Arkansas for Medical Sciences School of Medicine
  Associate Director, VA Health Services Research & Development Center for Mental Healthcare and Outcomes Research, Central Arkansas Veterans Healthcare System
- Judith Hyatt, Pharm.D (VA)
  Clinical Pharmacist (Psychiatry and Pharmacotherapy) VA Western New York Healthcare System
- Martha Sajatovic, MD
  Professor of Psychiatry and of Neurology, University Hospitals Case Medical Center
  Willard Brown Chair in Neurological Outcomes Research
  Director, Neurological and Behavioral Outcomes Center
- Todd Semla, Pharm.D, MS (VA)
  National Pharmacy Benefits Management (PBM) Clinical Pharmacy Program Manager - Mental Health & Geriatrics
  Clinical Pharmacy Specialist (Psychiatry and Geriatrics)
- Marcia Valenstein, MD, MS (VA)
  Staff Psychiatrist, VA Ann Arbor Healthcare System
  Senior Research Scientist, VA Health Services Research and Development Service and the Serious Mental Illness Treatment Research and Evaluation Center (SMITREC), VA Ann Arbor Healthcare System
  Professor of Psychiatry, University of Michigan
- Dawn Velligan, PhD
  Director, Division of Community Recovery, Research and Training
  Professor of Psychiatry, Henry B. Dielmann Chair, University of Texas Health Science Center, San Antonio
- Corrine Voils, PhD (VA)
  Research Health Science Specialist, Durham Center for Health Services Research in Primary Care, VA Health Sciences Research and Development Service
  Social Psychologist, Durham VA Medical Center
  Professor of Medicine, Division of General Internal Medicine, Duke University Medical Center
- Daina Wells, Pharm.D. (VA)
  Program Manager, Academic Detailing Program at the Department of Veterans Affairs
  VACO Pharmacy Benefits Management
  Clinical Pharmacist (Psychiatry and Pharmacotherapy)
- John Zeber, PhD, MHA (VA)
  Co-director, Health Outcomes Core, Center for Applied Health Research, Internal Medicine
  Investigator, Central Texas Veterans Healthcare System
  Associate Professor, Texas A&M Health Science Center College of Medicine
  Member, International Society for Pharmacoepidemiology Outcomes Research (ISPOR) and ISPOR National Working Group on Medication Compliance