# SUMMARY AND DISCUSSION

## INTRODUCTION

This systematic review was conducted to evaluate the benefits and harms of the routine screening pelvic examination in asymptomatic average risk non-pregnant adult women. [underlined: Our primary conclusion is that there are no data indicating that the performance of the routine pelvic examination in asymptomatic average risk women reduces morbidity or mortality from any condition other than cervical cancer]. For cervical cancer the recommended examination is visual inspection of the cervix and cervical swabs for cancer and HPV. Nevertheless pelvic examinations in asymptomatic women are often performed even when cervical cancer screening is not required. Commonly cited indications are to screen for ovarian cancer, prior to prescribing hormonal contraception, to detect sexually transmitted infections or other pathology, or simply as part of the well-woman exam.2,47

In this review we summarize the results of recent reviews and guidelines from major US health organizations for cervical cancer and sexually transmitted infections (i.e., Chlamydia and gonorrhea) screening and for initiation of hormonal contraception. For all other indications we performed and report results from a comprehensive search of the medical literature.

## CERVICAL CANCER SCREENING

During the speculum examination, cervical swabs for human Papillomavirus infection and for cervical cancer (Pap smears) may be obtained. According to the United States Preventive Services Task Force (USPSTF), Pap smears should be performed every 3 years in average risk women with a cervix who are 21 to 65 years old; or every 5 years in women age 30 to 65 years if co-testing for human Papillomavirus testing is performed (Grade A Recommendation, i.e., USPSTF recommends the service; high certainty that the net benefit is substantial). Average risk is defined as absence of personal history of cervical cancer or high-grade precancerous cervical lesion, in utero exposure to diethylstilbestrol, or immunocompromised status.6

Pap smears should not be performed in the following circumstances (all Grade D recommendations, i.e. USPSTF recommends against the service; moderate or high certainty that the service has no net benefit or that the harms outweigh the benefits): women under 21 years of age, even if sexually active; women over 65 years of age who have had adequate and negative prior screening and are not otherwise at high risk for cervical cancer; women who have had a hysterectomy with removal of the cervix and who do not have a history of a high-grade precancerous lesion (cervical intraepithelial neoplasia, grade 2 or 3) or cervical cancer.6

Similar recommendations have been issued by the Centers for Disease Control and Prevention, American College of Obstetricians and Gynecologists (ACOG), the American Cancer Society (ACS), the American Society for Clinical Pathology (ASCP), and the American Society for Colposcopy and Cervical Pathology (ASCCP).7,8.^48^

## SCREENING FOR CHLAMYDIA AND GONORRHEA

Chlamydia and gonorrhea are common sexually transmitted infections (STIs) that are often asymptomatic. These infections can cause serious complications in women including PID, infertility, and increased risk of ectopic pregnancy. Clinical trials have demonstrated that screening of high risk populations for Chlamydia reduces incidence of PID49,50 and many professional organizations, and the USPSTF, endorse such screening for all sexually active, non-pregnant women 24 years of age or younger and older women at increased risk.3,51-53 Sexually active pregnant or non-pregnant women of any age who are at increased risk should be screened for gonorrhea.53 The USPSTF is currently in the process of updating its recommendations for screening for gonorrhea and Chlamydia (http://www.uspreventiveservicestaskforce.org/uspstf/uspschlm.htm#update).

Although screening for Chlamydia and gonorrhea traditionally required a speculum examination to obtain endocervical samples, newer assays achieve high diagnostic accuracy with self-obtained specimens. For [underlined: Chlamydia], nucleic acid amplification tests (NAATs) perform well (i.e., high specificity and sensitivity) on either self-collected vaginal swabs or urine54 and are endorsed by the USPSTF.3,55 For [underlined: gonorrhea], NAA testing of self-collected vulvovaginal swabs is equivalent to NAA testing of clinician obtained endocervical samples;56 this test may not have adequate sensitivity for gonorrhea detection when performed on urine samples.55

Studies have shown that women of all ages, of varying education levels, and of diverse ethnic and racial groups are easily able to self-collect vaginal samples. Furthermore, these self-obtained samples are comparable to those obtained by clinicians and, most importantly, women prefer this to the more invasive speculum examination.57-59 Reflecting the widespread acceptance of this non-invasive screening strategy for sexually transmitted infections, ACOG recently issued an opinion stating that “NAA testing on urine samples or vaginal swab specimens is now an acceptable form of screening for gonorrhea and chlamydial infection.”2

Current screening recommendations for Chlamydia and gonorrhea as well as for other sexually transmitted infections diagnosed by blood tests (human immunodeficiency virus, syphilis, and hepatitis B) are shown in Appendix C.

## PRIOR TO INITIATING HORMONAL CONTRACEPTION

In the mid 1990's several professional organizations, including the World Health Organization and ACOG, published recommendations stating that routine pelvic examinations were not required prior to prescribing hormonal contraception for healthy asymptomatic women (summarized in Stewart, 2001).5 These women require only a medical history and a blood pressure measurement to rule out contraindications to birth control pills.5 Nevertheless, according to a recent survey of obstetrician-gynecologists and primary care providers in the US, about a third require a pelvic examination prior to provision of oral contraceptives.60 Other, somewhat older data indicate that fewer than 5% of practicing obstetrician-gynecologists in the US would fill a prescription for hormonal contraception unless a woman was up-to-date on cervical cancer screening.61 Requiring a pelvic examination prior to prescribing hormonal contraception may cause women, especially teen age women, to avoid or delay obtaining contraception due to fear of the exam,21,25 thus increasing their risk of unwanted pregnancy.

## OVARIAN CANCER

We identified no studies that evaluated the mortality and morbidity benefits of the routine pelvic examination (specifically the bimanual examination) as a screening test for ovarian cancer in asymptomatic average risk women. Even under ideal circumstances (i.e., examination under anesthesia by an experienced gynecologist) and in a population with a high pre-test probability of disease (i.e., women undergoing gynecologic surgery), the bimanual examination has a sensitivity of only 28% and a positive predictive value of 64% for detection of adnexal masses.62

The bimanual examination was not included as a screening modality in either of the 2 large contemporary trials of ovarian cancer screening. In the Prostate Lung Colorectal and Ovarian cancer (PLCO) study, a randomized controlled trial of over 78,000 women aged 55 to 74 years followed for a median of 12.4 years, the bimanual exam was initially included in the screening protocol but was dropped after 5 years because no cancers were detected solely by this examination.63 The second screening trial, the United Kingdom Collaborative Trial for Ovarian Cancer Screening (UKCTOCS), does not include pelvic examination in its screening protocol. This study of 202,638 post-menopausal women ages 50 to 74 years is comparing no screening, screening with annual CA-125 with transvaginal ultrasound as a second-line test, or transvaginal ultrasound and is expected to report mortality results in 2015.^64^

Results from the PLCO screening trial were disappointing. The screening tests included serum CA-125 (offered annually for 6 years) and transvaginal ultrasonography (offered annually for 4 years). Despite an increase in ovarian cancer detection rates in the screened group, mortality from ovarian cancer was not reduced.63 If these 2 tests, which have greater diagnostic accuracy than the bimanual examination, are not associated with decreased mortality from ovarian cancer, it is difficult to make the case that the less specific and sensitive bimanual examination should be used for ovarian cancer screening.

In the absence of evidence, most major professional and government groups recommend against screening for ovarian cancer in asymptomatic average risk women.65,66 For example, the Australian National Breast and Ovarian Cancer Centre stated there is no evidence that supports any form of screening for ovarian cancer, including the pelvic examination.67 A joint statement from ACOG and the Society of Gynecologic Oncologists states that there is “no effective strategy for ovarian cancer screening”.68 The American Cancer Society states that there is “no proven effective screening strategy for the early detection of ovarian cancer” and does not recommend screening asymptomatic women at average risk.69 In 2012, the United States Preventive Services Task Force (p 903) noted that “no randomized trial has assessed the role of the bimanual pelvic examination for cancer screening.”17 Further, it concluded that there is “at least moderate certainty that harms of screening for ovarian cancer [with transvaginal ultrasonography and serum tumor marker CA-125] outweigh the benefits”.17 Nevertheless, recent data indicate that about a third of US physicians continue to order these tests to screen for ovarian cancer.65

## PELVIC INFLAMMATORY DISEASE

We identified no studies investigating the benefits of the screening pelvic examination for the diagnosis of pelvic inflammatory disease. PID is a condition often presenting with vague or minimal symptoms70 which if left untreated can lead to infertility, ectopic pregnancy, or chronic pelvic pain.71-74 Nevertheless, the Centers for Disease Control and Prevention states that “the optimal treatment regimen and long-term outcome of early treatment of women with asymptomatic or subclinical PID are unknown” and recommends treatment only when a woman with some symptoms (e.g., lower abdominal or pelvic pain) has physical exam findings (e.g., cervical motion, uterine or adnexal tenderness) suggestive of PID.75 Symptom questionnaires are available to help determine which patients require a bi-manual examination for diagnosis of PID.76

## BACTERIAL VAGINOSIS

We identified one study of bacterial vaginosis that included both symptomatic and asymptomatic women (N=269, 67% asymptomatic), used a definitive gold standard test (Gram's stain), and performed the screening and gold standard tests in all participants.15 The screening test evaluated, known as the Amsel criteria, are characteristics of vaginal secretions obtained by swab during the pelvic examination.16 The prevalence of bacterial vaginosis (39%) was higher than usually reported. The sensitivity and specificity of the Amsel criteria were 69% and 93% respectively and were not reported separately for the subgroup of asymptomatic women.

Since this study included both symptomatic and asymptomatic women in whom the prevalence of bacterial vaginosis was high, the results may not be applicable to the average risk asymptomatic population that is the focus of this review. Furthermore the clinical significance of a diagnosis of bacterial vaginosis in asymptomatic women is unclear; many of these cases may represent overdiagnosis.77

## OTHER CONDITIONS

We identified no studies investigating the benefits of the screening pelvic examination for the diagnosis of other malignancies or other benign gynecologic conditions. Although several studies have documented a 2–4% prevalence of pelvic-examination-detected abnormalities in asymptomatic women, these studies did not determine if detection in the asymptomatic phase had any impact on patient outcomes.78,79

## PELVIC EXAMINATION-RELATED HARMS

We identified no studies that specifically investigated over-diagnosis, over-treatment, or diagnostic procedure-related harms resulting from findings on the pelvic examination performed in asymptomatic women. However data from one of the older screening studies indicated that screening pelvic examinations led to unnecessary surgery in 1.5% of women screened,14 exposing them to a major surgical complication risk that may be as high as 15%.63

Other harms include psychological distress in anticipation of, and during, the pelvic examination. In the 15 studies (N>13,000) that examined these outcomes, the percentage of respondents endorsing fear, embarrassment, or anxiety during or in advance of the pelvic examination ranged from 10 to 80% (median 34%, 7 studies, N=10,702). The percentage endorsing pain or discomfort during the pelvic exam ranged from 11 to 60% (median 35%, 8 studies, N=4,576). Women who endorsed pain or discomfort were less likely to return for another visit than those who did not experience pain or discomfort.

It has been hypothesized that women who have been victims of sexual violence (SV) are more likely to experience psychological harms from the pelvic examination. Our review however indicates that the data are mixed. Pain and discomfort were significantly more common in SV + compared to SV- women in only 2 of 4 studies39,45 and 2 of 3 studies found a significant association between history of SV and fear, anxiety, or embarrassment.40,42 Post traumatic stress disorder was evaluated as a co-variate in 2 controlled studies and was found to be significantly associated with pelvic examination-related fear, embarrassment, and distress, independent of SV history.39,40

Although our review focused on adult women it is worth noting that several groups have reported that younger women (e.g., age ≤ 25 years) are more likely than older women to experience pelvic examination-associated embarrassment and pain.29,30

Finally, it has been suggested that the opportunity for an annual pelvic examination might serve as an incentive for women to access the healthcare care system and thereby receive recommended gynecologic services such as contraception, screening for sexually transmitted infections and cervical cancer, and other non-gynecologic preventive care including immunizations, blood pressure, weight and cholesterol measurement, colon cancer screening, and risk factor assessment and counseling.35 Our literature search did not identify any studies that tested this hypothesis. Indeed, as discussed above, fear or anxiety about the pelvic exam is associated with reduced compliance with visits for Pap smears.

## PROVIDER ATTITUDES, BELIEFS AND PRACTICES

As documented in this report, the evidence does not support performance of the routine pelvic examination in asymptomatic women to screen for any condition other than cervical cancer. Nevertheless providers continue to perform this exam for a variety of reasons including prior to prescribing hormonal contraception, to diagnose sexually transmitted infections, or to screen for benign conditions or malignancies other than cervical cancer. A recent study, for example, reported that 33% of providers (obstetric-gynecology and family physicians and advanced practice nurses) said that they always and 44% said they usually require a pelvic exam prior to prescribing oral contraceptives.60

In addition, many providers perform the examination to obtain Pap tests for women in whom the test is not indicated (e.g., those who have had a hysterectomy for benign conditions or are younger than 21 years of age80 or at more frequent intervals than recommended (Perkins 2013). A recent study showed that primary care provider adherence to recommended screening intervals for cervical cancer screening was poor, with 67 to 94% of respondents stating they would perform subsequent screening sooner than recommended by contemporary guidelines.81 This overuse was recently high-lighted by the American Board of Internal Medicine Foundation's Choosing Wisely Campaign.80

Finally, many providers continue to include a pelvic examination as part of the well woman visit. Indeed, ACOG recommends annual routine pelvic examinations while acknowledging (p 422) that “this recommendation is based on expert opinion.”2 In a survey study of 1250 physicians in the US, 54% of internists, 90% of family practitioners and 98 % of obstetrician-gynecologists indicated that they perform pelvic examinations “as part of a well-woman exam.”1,82 In a clinical-vignette survey study of 521 obstetrician-gynecologists, over 95% indicated that they would perform a bimanual examination in asymptomatic women not due for a Pap test.47

Reasons for performing routine pelvic examinations include clinician preference, legal concerns, financial incentives and reimbursement, and the influence of medical training.2,35,82 In a small (n=27) study of US general practitioners, clinicians cited “patient reassurance, documenting the norm, ‘because I was taught to,’ for legal reasons, and for completeness” as a few of the reasons they continue the exam annually.35 In a recent survey of 521 US obstetrician-gynecologists, performing a routine pelvic examination was considered very important for adherence to standard medical practice (45% of respondents), patient reassurance (49%), detection of ovarian cancer (47%), and identification of benign conditions (54–59%). The authors of this study concluded that more provider education is required, particularly with regard to ovarian cancer screening.47

## CONCLUSIONS AND FUTURE DIRECTIONS

There are no data indicating that the performance of the routine pelvic examination in asymptomatic average risk women reduces morbidity or mortality from any condition other than cervical cancer. For cervical cancer screening, the pelvic examination only needs to include visual inspection of the cervix and collection of a cervical specimen for Pap testing and, if indicated, for human papillomavirus testing. A bimanual examination is not indicated for cervical cancer screening. Although the pelvic examination may detect abnormalities in about 2–4% of asymptomatic women, the vast majority of these conditions are of minimal clinical importance.78,79,83

Harms of the screening pelvic examination include unnecessary laparoscopies or laparotomies performed because of abnormalities detected on the speculum or bimanual examination. This occurs at a rate of about 1.5% and may expose these women to a 15% risk of one or more major surgical complications. Other harms of the examination include fear, embarrassment, or anxiety (in 10 to 80%, median 34%) and pain or discomfort (in 11 to 60%, median 35%). Victims of sexual violence may be more likely than other women to experience pelvic examination-related distress, fear and embarrassment. Women who endorse pain or discomfort are less likely to return for another visit than those who don't. We did not identify any studies that evaluated possible indirect benefits of the pelvic examination (e.g., as an incentive to women to seek healthcare).

Conducting a pelvic examination incurs substantial costs. It has been estimated that the total annual cost of preventive gynecologic exams and associated laboratory and radiologic services in the US is $2.6 billion.84 Medicare “National Payment Amount” values for 2013 are $38.11 for a screening pelvic examination and $45.93 for collection of a Pap smear specimen (www.cma.gov/apps/physician-fee-schedule/overview/aspx). It is likely that a substantial percentage of the annual cost represents unnecessary care, given that a majority of clinicians report performing routine pelvic examinations in asymptomatic women even if they are not due for a Pap smear and a substantial proportion report doing Pap smears more often than recommended.

Unnecessary pelvic examinations incur opportunity costs as well, including the time required for the examination and its preparation (patient disrobing and putting on a gown, clinician finding a chaperone, chaperone taking time away from other duties).

In conclusion, we found no data supporting the use of the screening pelvic examination (including speculum and bimanual examinations) in the asymptomatic average risk woman for any indication other than periodic cervical cancer screening. The procedure causes pain, discomfort, fear, anxiety and/or embarrassment in about a third of women. It is time and resource intensive, and can lead to unnecessary, invasive, and potentially harmful diagnostic procedures.85 The most important area for future research is development and testing of strategies to reduce the high rate of inappropriate use of the pelvic examination.86 Because the implementation literature suggests that passive education alone is unlikely to be effective87 a variety of strategies employed at multiple levels within the healthcare system will likely be required.88