# RESULTS

We identified 52 articles that met our inclusion criteria – 32 studies and 20 guidelines and related documents.

## LITERATURE FLOW

From the primary literature search, we identified 1523 abstracts. From the “Related Citations” literature search, we identified 826 unique abstracts for a total of 2349 abstracts. We excluded 2193 abstracts and reviewed the full text of 156 references. We excluded 143 articles during full text review leaving 13 eligible for inclusion. An additional 39 references were identified by hand-searching pertinent trials and related systematic reviews or were suggested by members of the Technical Expert Panel or peer reviewers. Figure 2 details the process.

Figure 2 Literature Flow

## KEY QUESTION #1 How accurate is the screening pelvic examination for the detection of malignancy (other than cervical), pelvic inflammatory disease (PID), or other benign gynecologic conditions?

A diagnostic accuracy study should include an appropriate population, use a definitive gold standard test, and perform the screening and gold standard tests in all participants (p 275).11 For this review, an appropriate population is defined as asymptomatic average risk women. Ovarian cancer and bacterial vaginosis were the only conditions for which we found diagnostic accuracy studies conducted in asymptomatic average risk women.

### Accuracy of the Pelvic Examination for Detection of Ovarian Cancer

Assessing the diagnostic accuracy of the pelvic examination for detection of ovarian cancer is problematic because the definitive gold standard is a pathologic diagnosis of cancer made on a surgical specimen and ethical concerns arise regarding performing biopsies in people with normal physical examinations or normal follow-up imaging studies (e.g., transvaginal or trans- abdominal ultrasound). The other option, employed in the 3 studies below, is to follow all women with normal pelvic examinations to assess the subsequent incidence of cancer and assume that within a given period of time (e.g., within one year) these cancers were present but missed at the time of the pelvic examination (false negatives). Therefore, while it is reasonable to expect researchers to conduct studies to assess the true and false positive rates (and positive predictive value) of the pelvic examination (as definitive testing is clinically indicated pursuant to an abnormal pelvic exam) it is unlikely that there will be any definitive studies assessing the true and false negative rates (and negative predictive value).

We identified 3 cohort studies that investigated the value of the pelvic examination for the detection of ovarian cancer in asymptomatic average risk women (Table 1).12-14 These three studies assembled an appropriate population and used a definitive gold standard test (biopsy results) but did not perform that test in all participants. Since the gold-standard test was not performed in all patients, sensitivity and specificity cannot be calculated. We therefore report only positive predictive values.

- Grover et al. screened 2623 healthy, asymptomatic women (mean age 51 years), with pelvic examination and serum cancer antigen (CA)-125 measurement.12 Forty women had adnexal abnormalities on pelvic examination (1.5%). All abnormalities were determined to be benign on further investigation and no cases of ovarian cancer developed in these 40 women during the 1 year follow-up. Therefore, the positive predictive value of the pelvic exam for ovarian cancer was 0%. The positive predictive value of the pelvic examination for benign abnormalities including dermoid cysts, endometriosis, simple cysts, cystadenoma, or fibromas was 22%.12
- Jacobs et al. screened 1010 healthy, asymptomatic, post-menopausal women (median age 54 years), with pelvic examination and serum CA-125 measurement.13 If either of these was abnormal a transabdominal ultrasound was performed within 4 weeks. If the ultrasound was normal women were followed for one year with ultrasounds and serum CA-125s every 3 months. If the ultrasound was abnormal the woman was referred to her primary care physician for further consultation. Adnexal abnormalities were present on pelvic examination in 28 women (2.8%). In these 28 women, 1 case of ovarian cancer was diagnosed at laparotomy resulting in a positive predictive value of 3.6% for the pelvic examination alone. The addition of the CA-125 did not change the positive predictive value of the pelvic examination alone because among the 28 women with abnormal pelvic examination, the CA-125 was elevated in only the one case of ovarian cancer.13
- Adonakis et al. screened 2000 healthy, asymptomatic women aged 45 years or older (mean age 58.1 years), with pelvic examination and CA-125 measurement.14 If either of these was abnormal a transvaginal ultrasound was performed. If the ultrasound was normal the women were followed for one year with ultrasound and CA-125 every 3 months. Women who had an abnormal ultrasound were referred for “further management.” One hundred and seventy four women had abnormal or ambiguous pelvic examinations. In these 174 women, 2 cases of ovarian cancer were diagnosed at laparotomy resulting in a positive predictive value of 1.2% for the pelvic examination alone. The positive predictive value of an abnormal or ambiguous pelvic exam PLUS an elevated CA-125 was 2/12 (17%).14

Table 1 Prospective Cohort Studies of Diagnostic Accuracy of the Screening Pelvic Examination for Detection of Ovarian Cancer in Asymptomatic, Average-Risk Women

Author, Year Country | Reference Standard | Population | Findings | One Year Incidence of Ovarian Cancer n/N (%) | Positive Predictive Value | Harms | | Study Quality (# of QUADAS Elements Met^*^)
Author, Year Country | Reference Standard | Population | Findings | One Year Incidence of Ovarian Cancer n/N (%) | Positive Predictive Value | Abnormal Pelvic Exams | Laparoscopic or Open Surgery | Study Quality (# of QUADAS Elements Met^*^)
Adonakis 1996^14^ Greece | Surgery and histology | N=2000 Age 45 and older with no evidence of adnexal pathology Mean age: 58 years (45 to 80) | Abnormal pelvic exam: 59/2000 (3.0%) Ovarian cancer if abnormal exam: 1/59 (1.7%) Ambiguous pelvic exam: 115/2000 (5.8%) Ovarian cancer if ambiguous exam: 1/115 (0.9%) | 2/2000 (0.10%) | 1.2% | 174 | 31 | 8
Grover 1995^12^ Australia | Surgery | N=2623 Healthy, asymptomatic Mean age: 51 years (25 to 92) | Abnormal adnexa on pelvic exam: 40/2623 (1.5%) Ovarian disease: 9/40 (PPV=22%) (all benign) One cancer case reported at 12 month follow-up^†^ | 1/2623 (0.04%) | 0%^‡^ | 40 | NR | 8
Jacobs 1988^13^ United Kingdom | Surgery and histology | N=1010 Healthy, age 45 and older, amenorrheic for >12 months Median age: 54 years (45 to 83) | Abnormal pelvic exam: 28/1010 (2.8%) Ovarian cancer if abnormal exam: 1/28 (3.6%) No additional cancer cases at 12 month follow-up∥ | 1/1010 (0.10%) | 3.6% | 28 | NR^§^ | 8

NR = Not Reported

* All studies were rated identically on the 11 QUADAS elements.(Reitsma 2009)9 1) Representativeness: Yes; 2) Acceptable reference standard: Yes; 3) Acceptable delay between tests: Yes; 4) Whole or random sample verification: No; 5) Same reference standard: No; 6) Reference test independent of index: Yes; 7) Index test results blinded: No; 8) Reference standard blinded: Yes; 9) Relevant clinical information available: Yes; 10) Uninterpretable results reported: Yes; 11) Withdrawals explained: Yes

† All women were sent a questionnaire at 1 year follow-up; the response rate was 83%

‡ No cases of ovarian cancer were detected in women with an abnormal pelvic examination

§ 13 women with abnormal ultrasound findings were advised to consult their general practitioner for possible referral to a gynecologist

∥ Follow-up included CA-125 and ultrasound if initial testing was abnormal or a postal questionnaire if initial testing was normal

### Accuracy of the Pelvic Examination for Detection of Bacterial Vaginosis

We identified one study of bacterial vaginosis that included asymptomatic women, used a definitive gold standard test, and performed the screening and gold standard tests in all participants.15 The screening test evaluated, known as the Amsel criteria, were the following characteristics of vaginal secretions obtained by swab during the pelvic examination: thin, homogeneous consistency; pH greater than 4.5; presence of clue cells on microscopic evaluation; and release of amine odor following the addition of a base (whiff test). The presence of 3/4 of these criteria is generally considered diagnostic of bacterial vaginosis.16 The gold standard was Gram's stain. The study was a prospective observational study of 269 women undergoing a pelvic examination at a University-based clinic in Rhode Island. Sixty seven percent of women were asymptomatic. The prevalence of bacterial vaginosis by Gram's stain was 39%. The sensitivity and specificity of the Amsel criteria were 69% and 93% respectively.

Since this study included both symptomatic and asymptomatic women in whom the prevalence of bacterial vaginosis was higher than generally reported, the results may not be applicable to the average risk asymptomatic population that is the focus of this review.

### Summary

We identified no studies of diagnostic accuracy of the pelvic examination for ovarian cancer that applied the gold standard test to all patients; thus, true sensitivity and specificity cannot be determined. However, the positive predictive value of the pelvic examination alone for the detection of ovarian cancer in asymptomatic women in the reviewed studies was low (1.2-3.6%).

We identified one study that evaluated the accuracy of the Amsel criteria for diagnosing bacterial vaginosis. The sensitivity and specificity were 69% and 93%, respectively. Since this study included both symptomatic and asymptomatic women in whom the prevalence of bacterial vaginosis was higher than generally reported, the results may not be applicable to the average risk asymptomatic population that is the focus of this review.

We identified no studies that assessed the diagnostic accuracy of the pelvic examination for PID, other gynecologic cancers, or benign conditions.

## KEY QUESTION #2 What are the benefits (reduced mortality and morbidity) and harms (over-diagnosis, over-treatment, diagnostic procedure-related) of the routine screening pelvic examination performed for the detection of malignancy, PID, or other benign gynecologic conditions?

### Benefits

#### Ovarian Cancer

We found no studies that assessed the benefits (reduced mortality or morbidity) of routine pelvic examinations for the detection of ovarian cancer in asymptomatic average risk women. Although labeled as screening studies, the three year-long cohort studies discussed under Key Question#1 were not designed to evaluate the effect of screening on ovarian cancer-related morbidity or mortality outcomes.12-14

In 2012 the USPSTF stated that there is “at least moderate certainty that harms of screening for ovarian cancer outweigh the benefits.” The screening modalities evaluated were transvaginal ultrasonography and testing for the serum tumor marker CA-125. The report comments that there are no randomized clinical trials assessing the role of the pelvic exam for cancer screening and that the pelvic examination was not a focus of its review.17 A complete discussion of screening for ovarian cancer with modalities other than the pelvic examination is included in the discussion section, below.

#### Other Malignancies

We found no studies that assessed the benefits of routine pelvic examinations for the detection of uterine, bladder, vaginal or vulvar cancer in asymptomatic average risk women.

#### PID and Other Benign Gynecologic Conditions

We found no studies that assessed the benefits of screening asymptomatic women with routine pelvic exams for PID, fibroids, warts, atrophic vaginitis, or any other gynecological condition.

### Harms

Direct harms of the pelvic examination itself (e.g., pain, discomfort, embarrassment) are discussed under Key Question #3. We include here harms related to false reassurance, over-diagnosis, over-treatment, or diagnostic procedure-related harms that result from findings on the pelvic examination performed in asymptomatic women. We identified no studies that directly investigated any of these harms. However, one of the studies on diagnostic accuracy of the pelvic examination for detection of ovarian cancer in asymptomatic average risk women provides some indirect evidence, as shown in Table 1.^14^ In this study there were 174 abnormal screening pelvic examinations in 2000 average risk asymptomatic women (8.7%). These 174 women received follow-up with either a transvaginal or transabdominal ultrasound plus a serum CA-125. Based on the results of these follow-up tests, 31 women (18%) underwent either open or laparoscopic surgery which revealed ovarian cancer in 2 women (6.5%). Thus screening pelvic examination led to unnecessary surgery in 29/2000 women or 1.5% of women.

### Summary

We identified no studies that evaluated the benefits and harms of the routine pelvic examination as a screening test for ovarian cancer in asymptomatic average risk women. Indirect data suggest that such screening would lead to unnecessary surgery for 1.5% of women screened. We identified no studies investigating the benefits of the screening pelvic examination for the diagnosis of other malignancies, PID, or other benign gynecologic conditions.

## KEY QUESTION #3 What are the examination-related harms and indirect benefits of performing a screening pelvic examination in asymptomatic women?

### Harms

The pelvic examination includes insertion of a speculum and examiner fingers (for a bi-manual examination) into the vagina. Anticipating and undergoing such an examination may cause psychological harms (fear, anxiety, embarrassment, pain, discomfort).

Although physical harms (urinary tract infections and symptoms such as dysuria, and frequency) have been reported by one investigator group, these results should be interpreted with caution given substantial methodological weaknesses including inadequate control for confounding and incomplete follow-up.18,19 Hypothesized mechanisms include microtrauma, alteration of normal flora, or inoculation of the urinary tract with vaginal flora from insertion of the speculum and examiner fingers and use of lubricant.

#### Psychological Harms (Fear, Anxiety, Embarrassment, Pain or Discomfort)

We identified 15 studies that examined women's attitudes toward and/or experiences of the routine pelvic examination; 14 surveys20-33 and 1 longitudinal cohort study (Table 2). 34 Nine were conducted in the US, two in Sweden, and one each in Jamaica, England, Scotland, and New Zealand. Median sample size was 409 (range: 40 to 7168). Generally the studies included only women in their reproductive years. In three of the nine US studies, ethnic and racial minorities were well represented.27,28,34 Reported outcomes were diverse, including fear, anxiety, embarrassment, pain, discomfort and global assessment of the pelvic examination experience. Since all the studies used different outcome measures, it was not possible to pool the data. Five studies reported the association between psychological harms and self-reported adherence to return gynecologic visits or Pap smears.21,23,27,28,34 Three of these used multivariable analysis.27,28,34

Table 2 Pelvic Examination-related Psychological Harms: Frequency and Impact (k=15)

Study/Date/Type | Population/Setting/N (Response Rate) | Psychological Harms | | | Impact on Return Visits
Study/Date/Type | Population/Setting/N (Response Rate) | Fear, Anxiety, Embarrassment | Pain, Discomfort | Global Assessment | Impact on Return Visits
Osofsky, 1967^26^ Survey | N=40 (RR not reported) Single clinic in US Ages 20 to 39 years | Anxiety: 32/40 (80%)
Hesselius, 1975^23^ Survey | N=800 (RR 88%) Population-based in Sweden Women invited to mass screening Ages 21 to 49 years | 25% said “exam was not at all unpleasant” | 74% said exam “not at all painful” | | MVA: No Participants in screening were less likely than non-participants to endorse “unpleasantness” of the exam although it is unclear if this finding was statistically significant
Haar, 1977^32^ Survey | N=409 (RR not reported) Multiple clinics in New York Ages “under 20 to over 60” years | 34% endorsed moderate or severe anxiety before a visit to the gynecologist; a similar % endorsed these same feelings about general medical check-ups.
Petravage, 1979^33^ Survey | N=977 (RR not reported) 14 clinics in Utah No age restrictions, median age 28.4 years | | 45% “felt comfortable during a pelvic examination”
Golomb, 1983^20^ Survey | N=61/70 (RR 87%) 2 clinics in Rhode Island Ages 18 or older | | | 86% reported that pelvic examinations are “not all that bad”
Broadmore, 1986^31^ Survey | N=199/250 (RR 80%) Family planning clinic in New Zealand “mostly aged 17 to 30” years | | 60% reported some pain or discomfort during the examination
Wijma, 1998^24^ Survey | N=531/788 (RR 67%) Population-based in Sweden Ages 25 to 49 years | | Among women who were ≦19 years old at first pelvic exam, 71% reported that it was painful | 75% rated the pelvic examination as ≥ 46 on a scale of 0 (very negative) to 100 (very positive)
Yu, 1998^30^ Survey | N=650 (RR not reported) Had a Pap smear (Pap +: N=523) Did not have a Pap smear (Pap -: N=127) 2 hospital-based clinics in London Ages 15 to 75 years | Pap +: 15% embarrassing Pap -: 13% embarrassed | Pap +: 11% painful Pap -: 4% painful | Pap +: 3% troublesome Pap -: 12% troublesome; 13% scared
Harper, 2001^21^ Telephone Survey | N=800 (RR not reported) Low-income residents of California Ages 18 to 44 years | 75% endorsed fear and embarrassment | | | No statistical analysis done 31% said feelings of fear and embarrassment had prevented them from getting a pelvic exam at some time
Fiddes, 2003^29^ Survey | N=687/1000 (RR 69%) Family planning or sexual health clinics in Scotland Age: 8% ≤ 20, 50% 21–40, 42% >40 years | 10% feel anxious or distressed at the prospect of a pelvic examination | | Older women and women who had been pregnant were significantly and independently less likely to “feel negative towards pelvic examination”
Kahn, 2003^34^ Cohort Study | N=490 Urban hospital in Cincinnati Ages 12 to 24 (44% < 18 years) 44% black; 24% hispanic | | 61% believed Pap would not be painful | | MVA: yes [underlined: Lack of pain] associated with return visit (OR 1.73, 95% CI: 1.08 to 2.83) [underlined: Embarrassment] not significantly associated with return visit These outcomes did not differ by race/ethnicity.
Taylor, 2004^28^ Survey | N=370/449(RR 82%) Population-based in Seattle Ages 18 to 64 years All Vietnamese-American | | 31% endorsed pain | | MVA: yes Concern about pain and discomfort was NOT a significant barrier to Pap testing (OR 0.5, 95% CI: 0.3 to 1.1)
Hoyo, 2005^27^ Survey | N=144/172 (RR 84%) Population-based, Durham, NC Ages 45 to 64 years | | 24% endorsed pain | | MVA: yes Pain associated with Pap non-adherence (OR 4.8, 95% CI: 1.7 to 13.7)
Bourne, 2010^22^ Survey | N=7168 Population based, Jamaica Ages 15 to 49 years | Among the 57% who had never had a pelvic exam, 0.5% endorsed embarrassment as the reason | | Among the 57% who had never had a pelvic exam, 1.4% said the reason was they did “not like the process” 0.1% did “not like the environment”
Armstrong, 2012^25^ Survey | N=148/635 (RR 23%) Planned Parenthood Clinic in Virginia Ages 18 to 27 years | 17% endorsed fear 16% endorsed embarrassment

RR = response rate; MVA = multivariable analysis; OR = odds ratio; CI = confidence interval

The overall quality of the studies was low. Most studies enrolled a convenience sample (i.e., women attending family planning, primary care or other clinics). Five were population based22-24,27,28 and three of these recruited a random sample of the population.22,24,28 One study developed the survey instrument based on focus group responses;27 three studies reported pretesting or piloting the instrument.25,28,29 Although the cohort study compared characteristics of participants who stayed in the study with those who were lost to follow-up,34 none of the survey studies provided a comparison of responders and non-responders.

The percentage of women endorsing pain or discomfort during the pelvic exam ranged from 11 to 60% (median 35%; 8 studies, N=4576). The percentage endorsing fear, embarrassment, or anxiety ranged from 10 to 80% (median 34%; 7 studies, N=10,702). One study reported that women were more likely to report pain at their first (71%) compared to their last (33%) examination.24 Similarly, another study reported that older age and previous pregnancy were both independently associated with less negative feelings towards the pelvic examination.22

All five studies that examined the relationship between pelvic-examination pain or discomfort and return visits, reported that women who endorsed pain or discomfort were less likely to return for another visit. The three studies that used multivariable statistical analysis are described here. In the largest and most methodologically rigorous of these, Kahn et al. found that women who had not experienced pain were 73% more likely to return for another examination than those who had experienced pain (OR 1.73, 95% CI 1.08 to 2.83, N=490).34 In the smallest study conducted in middle-aged African American women, the perception of pain on a Pap test was significantly associated with non-adherence to future tests (OR 4.8, 95% CI 1.7 to 13.7, N= 144).27 The third study of exclusively Vietnamese American women (N=370) reported that only 55% of women who endorsed pain or discomfort had a Pap smear in the previous 3 years compared with 74% of those who did not endorse pain or discomfort (P<0.001). This association remained significant in multivariable analysis (OR and 95 % CI not reported).28 One of these studies also examined the association between embarrassment and return visits and found that embarrassment was not significantly associated with likelihood of return visit.34

##### Summary of Psychological Harms

We identified 15 studies of more than 13,000 women conducted in 6 countries that reported psychological harms. The percentage endorsing fear, embarrassment, or anxiety ranged from 10 to 80% (median 34%, 7 studies). The percentage of women endorsing pain or discomfort during the pelvic exam ranged from 11 to 60% (median 35%, 8 studies). Women who endorsed pain or discomfort were less likely to return for another visit than those who did not experience pain or discomfort.

### Indirect Benefits

It has been suggested that the annual pelvic examination might serve as an incentive for women to access the healthcare care system and thereby receive recommended gynecologic services such as contraception, screening for STIs and cervical cancer and other non-gynecologic preventive care including immunizations, blood pressure, weight and cholesterol measurement, colon cancer screening, and risk factor assessment and counseling.35 Our literature search did not identify any studies that tested this hypothesis. Indeed, as discussed above, fear or anxiety about the pelvic exam is associated with lower compliance with visits for Pap smears.

## KEY QUESTION #3A Do these harms vary by patient or provider characteristics?

We looked for studies investigating factors that might moderate the association between pelvic examinations and harms. [underlined: Patient factors] include demographics and physical traits, history of sexual trauma and/or post-traumatic stress disorder, and veteran status. [underlined: Provider factors] include gender and specialty. The only harms for which we found data were psychological harms

### Patient Factors

#### Obesity

We identified one study that reported pelvic examination-associated psychological harms in women of varying body weights36 and one that evaluated weight as a predictor of return visits.37 The quality of both studies was low. Both enrolled a convenience sample and in one study36 there was no adjustment for oversampling. One study used a survey instrument developed based on focus group data;36 the other study provided no information about the development of the survey instrument.37 Neither study provided information on whether non-responders were similar to responders.

A community-based study of attitudes and behavior related to gynecologic care in California surveyed 498 overweight women (response rate not reported) purposefully selected to include a high percentage of African Americans (32%).^3^6 Ages ranged from 21 to 80 years, BMI from 25 to 122 kg/m2. Over 90% had health insurance. Overall, 41% reported delaying seeking healthcare because of their weight and 52% considered their weight to be a barrier to getting appropriate healthcare. BMI was an independent and significant predictor of the patient perception that weight was a “barrier to health care” and a factor in “delay of care.” Women in the highest BMI category also had a significantly lower rate of Pap test completion in the previous 2 years compared to women with lower BMIs, after controlling for age and race. Furthermore, heavier women were significantly more likely than thinner women to endorse feelings of disrespect and embarrassment during a gynecology visit.36

A community-based study in Connecticut surveyed 303 women between the ages of 40 and 65 years (response rate 96%) to determine rates and predictors of screening pelvic examinations in overweight and non-overweight women.37 Sixty-six percent of the respondents were classified as average weight, 20% as moderately overweight, and 14% as very overweight. Significantly fewer very overweight women (48%) reported annual pelvic examinations than average weight (68%) or moderately overweight (67%) women. The only “attitude” investigated in this study was intention to get an exam (“reluctant”, “they are routine”, and “I schedule them annually”) which was highly correlated with actual behavior.37 This study did not investigate possible harms of the pelvic examination such as fear, embarrassment, anxiety, pain or discomfort.

#### History of Sexual Violence (Table 3)

Table 3 History of Sexual Violence (SV) as a Predictor of the Pelvic Examination Experience and Receipt of Pap Smears (k=9)

Study/Year/Design | Population/Setting | Predictors | Outcomes | Findings
Lee, 2007^38^ In-person survey, no control group | N=31/46 (Response Rate 67%) SV+ female veterans VA clinic | PTSD | Anticipated PE-related distress | No association between PTSD symptom severity and anticipated PE-related distress
Weitlauf, 2008^39^ Survey (immediately after routine PE) | N=68/94 (Response Rate 72%) Female veterans 77% SV+ 22% PTSD 18 to 65 years VA clinic | SV PTSD (current) | Distress Pain Both measured on Likert scales, 0-10 | [underlined: Distress (median)] SV+ 4.27 SV- 0 P=0.03 [underlined: Pain (median)] SV+ 2.5 SV- 0 P=0.04 SV+ women with PTSD had significantly increased distress (but not pain) compared to women without PTSD (either SV+ or SV-) (P=0.02)
Weitlauf, 2010^40^ Survey | N=90/165 (Response Rate 55%) SV-, no PTSD: 17 SV+, no PTSD: 48 SV+ and PTSD: 22 Female veterans 18 to 65 years VA clinic | SV PTSD (current) | Fear Embarrassment Distress Pain Each measured on Likert scales | Median scores for fear, embarrassment, and distress were significantly higher in the SV+ plus PTSD group than the SV-, no PTSD group (Ps <0.005) and the SV+ no PTSD group (Ps <0.001)
Hilden, 2003^45^ Mailed Survey (1 week following PE) | N=808/1,011 (Response Rate 80%) 165 SV+ Age ≧18 years Denmark University hospital clinic | SV | Discomfort | On multivariate analysis, SV+ women were significantly more likely to report discomfort than SV- women (OR 1.85, 95% CI: 1.19 to 2.87)
Robohm, 1997^42^ Mailed survey | N=74 (Response Rate: NR) SV+ 44 SV- 30 population-based, small mid-western US city | SV | Distress Physical pain, discomfort Receipt of gynecological care Embarrassment, shame, fear | [underlined: Distress]: significantly higher in SV+ than SV- (P<0.01) [underlined: Physical pain or discomfort:] no significant difference SV+ significantly less likely to [underlined: seek regular gyn care] (P<0.05) All 3 significantly higher in SV+ than SV- (P<0.05, 0.01. 0.05, respectively)
Leeners, 2007^41^ Case-control, Mailed survey | N=255 (Response Rate: NR) SV+ 85 SV- 170 Germany | SV | % endorsing assumption “that a visit to the GYN would cause an important psychological strain” Receipt of gynecologic services | SV+ 37.7 SV- 3.5 P<0.0001 No significant difference in self-reported receipt of GYN services
Farley, 2002^43^ Mailed survey | N= 364/1,314 w/ Pap test in prior 2 yrs; 372/2897 without (Response Rate 17%) Age 21 to 64 years SV+ 26% HMO in California | SV | Receipt of Pap test in past 2 years | On multivariate analysis, SV was associated with a significantly lower odds of Pap smear receipt in past 2 years (OR 0.56, 95% CI: 0.34 to 0.91)
Lang, 2003^46^ Mailed survey | N=221/419 (Response Rate 56%) Mean age 46.6 SV+ 96 SV- 122 Primary care clinic at San Diego VA | SV | Mean number of Pap tests in past 5 years | SV+ 4.5 (SD 2.5) SV- 3.8 (SD 2.0) P<0.05
Watson-Johnson, 2012^44^ Telephone survey (Behavioral Risk Factor Surveillance System) | N=35,048 women (Response Rate: NA) SV+ 5,404 SV- 29,644 US population based | SV | % of women age ≥ 18 with Pap test within prior 3 yrs | SV+ 85.6 (SE 1.2) SV- 84.3 (SE 0.5) P=0.32

NR = not reported; PTSD = post traumatic stress disorder; PE = pelvic examination; SV = sexual violence; VA = Veterans Affairs; OR = odds ratio; CI = confidence interval; SD = standard deviation; HMO = health maintenance organization

We identified nine studies (eight with a control group), that focused on women with a history of sexual violence (SV). Two were from Europe and seven from the US. Five of the US studies were conducted in the VA, three of these at a single VA medical center.38-40 Outcomes included psychological harms only (k=6), self-reported utilization of gynecologic care only (k=3), or both (k=2).41,42 Eight of the nine studies were cross-sectional survey studies38-40,42-46 and one was a case-control study.41 The two studies by Weitlauf also evaluated the effect of PTSD on the pelvic examination experience.39,40

Overall, the studies were of low quality. Most enrolled a convenience sample with only two being population-based and studying a random sample of the population.43,44 In six studies, the survey or interview tool was either validated (five studies)38,39,43-45 or piloted (1 study).42 One study reported using only complete surveys;41 no other study commented on missing data. Characteristics of responders and non-responders were reported in one study.40 Another study compared responders to the general clinic population.46

In the 8 studies that included a control group, outcomes included pain and discomfort (k=4), fear, anxiety, or embarrassment (k=3), and receipt of gynecologic services (k=5). Two of the 4 studies reporting pain and discomfort found significantly higher rates in women with a history of SV compared to women without a history of SV; in the other 2 studies there was no difference. Two of the 3 studies reporting fear anxiety or embarrassment found that women with a history of SV were significantly more likely to endorse these emotions than women without a history of SV.

A survey study of 94 women (response rate 72%) from a single VA medical center, reported that women with a history of SV who also had symptoms of PTSD reported significantly more pelvic examination-related distress than women without PTSD.39 A second study from the same group (N=165, response rate 55%) reported significantly higher median scores for fear, embarrassment, and distress in women who had a history of SV and a diagnosis of PTSD than in women without PTSD, irrespective of their SV history.40 In both studies, levels of reported pain did not differ between women with and without a history of SV.

Five studies assessed receipt of gynecological services.41-44,46 Three were population-based,42-44 one enrolled primary care patients at a VA,46 and one was a case-control study from Germany.41 The findings in these five studies were inconsistent, with two finding decreased utilization in women with a history of SV, two finding no difference, and one finding increased utilization in women with a history of SV. The methodologically strongest of these studies was the analysis of data from the Behavioral Risk Factor Surveillance System, a population-based telephone survey of a nationally representative US sample.44 In this study of 35,048 women the prevalence of self-reported sexual violence was 15%. The percentage of women 18 or older reporting a Pap test within the prior 3 years did not differ between women with and without a history of SV (85.6% v. 84.3%, P=0.32)

### Provider Factors

We identified no studies that investigated the association between provider characteristics and psychological harms.

### Summary

Women who are very overweight may be less likely than other women to get Pap tests, possibly due to feelings of embarrassment (2 studies).

We identified nine studies that investigated the association between a history of sexual violence (SV) and experience of the pelvic examination or receipt of gynecologic services. Two of four studies found significantly higher rates of pelvic examination related pain and discomfort in SV+ women compared to SV- women. Two of three studies found a significant association between history of SV and fear, anxiety, or embarrassment during a pelvic examination. Among the five studies reporting receipt of gynecologic services, two found increased utilization, two found decreased utilization, and one (the methodologically strongest) found no difference in utilization between women with and without a history of SV. Women with a history of SV who also have a diagnosis of PTSD have significantly more distress, fear, and embarrassment than either SV+ or SV- women without PTSD (2 studies).