# REFERENCES

1 Stormo AR, Hawkins NA, Cooper CP, Saraiya M. The pelvic examination as a screening tool: practices of US physicians. Arch Intern Med. 2011;171:2053-4. [pmid: 22158576].
2 American College of Obstetricians and Gynecologists. Well-woman visit. Committee Opinion No. 534. Obstet Gynecol. 2012;120(2 Pt 1):421-4. [pmid: 22825111].
3 Meyers DS, Halvorson H, Luckhaupt S, U.S. Preventive Services Task Force. Screening for chlamydial infection: an evidence update for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;147(2):135-42. [pmid: 17576995].
4 Centers for Disease Control and Prevention. Screening Tests to Detect Chlamydia trachomatis and Neisseria gonorrhoeae Infections — 2002. MMWR. 2002;51(No. RR-15):1-38.
5 Stewart FH, Harper CC, Ellertson CE, Grimes DA, Sawaya GF, Trussell J. Clinical breast and pelvic examination requirements for hormonal contraception: current practice vs evidence. JAMA. 2001;285(17):2232-9. [pmid: 11325325].
6 Moyer VA, U.S. Preventive Services Task Force. Screening for cervical cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;156(12):880-91. [pmid: 22711081].
7 American College of Obstetricians and Gynecologists Committee on Practice Bulletins-Gynecology. Screening for cervical cancer. Practice Bulletin No. 131. Obstet Gynecol. 2012;120:1222-38. [pmid: 23090560].
8 Saslow D, Solomon D, Lawson HW, et al., for the ACS-ASCCP-ASCP Cervical Cancer Guideline Committee. American Cancer Society, American Society for Colposcopy and Cervical Pathology, and American Society for Clinical Pathology screening guidelines for the prevention and early detection of cervical cancer. CA Cancer J Clin. 2012;62:147-72. [pmid: 22422631].
9 Reitsma JB, Rutjes AWS, Whiting P, Vlassov VV, Leeflang MMG, Deeks JJ. Chapter 9: Assessing methodological quality. Deeks JJ, Bossuyt PM, Gatsonis C, editors. Cochrane Handbook for Systematic Reviews of Diagnostic Test Accuracy Version 1.0.0. The Cochrane Collaboration. 2009. Available from: http://srdta.cochrane.org/. 8 May 2013.
10 Whiting P, Rutjes AW, Reitsma JB, Bossuyt PM, Kleijnen J. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
11 Haynes RB, Sackett DL, Guyatt GH, et al. Clinical Epidemiology: How to do Clinical Practice Research. 3rd edition. Philadelphia. Lipincott Williams & Wilkins. 2006.
12 Grover SR, Quinn MA. Is there any value in bimanual pelvic examination as a screening test. Med J Aust. 1995;162(8):408-10. [pmid: 7746172].
13 Jacobs I, Stabile I, Bridges J. Multimodal approach to screening for ovarian cancer. Lancet. 1988;1(8580):268-71. [pmid: 2893084].
14 Adonakis GL, Paraskevaidis E, Tsiga S, Seferiadis K, Lolis DE. A combined approach for the early detection of ovarian cancer in asymptomatic women. Eur J Obstet Gynecol Reprod Biol. 1996;65(2):221-5. [pmid: 8730628].
15 Gutman RE, Peipert JF, Seitzen S, Blume J. Evaluation of clinical methods for diagnosing bacterial vaginosis. Obstet Gynecol. 2005;105:551-6. [pmid: 15738023].
16 Amsel R, Totten PA, Spiegel CA, Chen KC, Eschenbach D, Holmes KK. Nonspecific vaginitis. Diagnostic criteria and microbial and epidemiologic associations. Am J Med. 1983;74(1):14-22. [pmid: 6600371].
17 Moyer VA, U.S. Preventive Services Task Force. Screening for ovarian cancer: U.S. Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. 2012;157:900-4. [pmid: 22964825].
18 Tiemstra JD, Chico PD, Pela E. Genitourinary infections after a routine pelvic exam. J Am Board Fam Med. 2011;24(3):296-303. [pmid: 21551402].
19 Tiemstra JD, Pela E. Urinary symptoms after a routine pelvic exam. J Am Board Fam Med. 2011;24(3):290-5. [pmid: 21551401].
20 Golomb D. Attitudes toward pelvic examinations in two primary care settings. R I Med J. 1983;66(7):281-4. [pmid: 6577533].
21 Harper C, Balistreri E, Boggess J, Leon K, Darney P. Provision of hormonal contraceptives without a mandatory pelvic examination: the first stop demonstration project. Fam Plann Perspect. 2001;33(1):13-8. [pmid: 11271540].
22 Bourne PA, Charles CA, Francis CG, South-Bourne N, Peters R. Perception, attitude and practices of women towards pelvic examination and Pap smear in Jamaica. N Am J Med Sci. 2010;2(10):478-86. [pmid: 22558551].
23 Hesselius I, Lisper HO, Nordström A, Anshelm-Olson B, Odlund B. Comparison between participants and non-participants at a gynaecological mass screening. Scand J Soc Med. 1975;3(3):129-38. [pmid: 1215854].
24 Wijma B, Gullberg M, Kjessler B. Attitudes towards pelvic examination in a random sample of Swedish women. Acta Obstet Gynecol Scand. 1998;77:422-8. [pmid: 9598951].
25 Armstrong L, Zabel E, Beydoun HA. Evaluation of the usefulness of the ‘hormones with optional pelvic exam’ programme offered at a family planning clinic. Eur J Contracept Reprod Health Care. 2012;17(4):307-13. [pmid: 22524280].
26 Osofsky HJ. Women's reactions to pelvic examination. Obstet Gynecol. 1967;30(1):146-51. [pmid: 6027483].
27 Hoyo C, Yarnall KSH, Skinner CS, Moorman PG, Sellers D, Reid L. Pain predicts non-adherence to Pap smear screening among middle-aged African American women. Prev Med. 2005;41:439-45. [pmid: 15917039].
28 Taylor VM, Yasui Y, Burke N, et al. Pap testing adherence among Vietnamese American women. Cancer Epidemiol Biomarkers Prev. 2004;13(4):613-9. [pmid: 15066927].
29 Fiddes P, Scott A, Fletcher J, Glasier A. Attitudes towards pelvic examination and chaperones: a questionnaire survey of patients and providers. Contraception. Apr. 2003;67(4):313-7. [pmid: 12684154].
30 Yu CKH, Rymer J. Women's attitudes to and awareness of smear testing and cervical cancer. Br J Fam Plann. 1998;23:127-33. [pmid: 9882766].
31 Broadmore J, Carr-Gregg M, Hutton JD. Vaginal examinations: women's experiences and preferences. N Z Med J. 1986;99(794):8-10. [pmid: 3456108].
32 Haar E, Halitsky V, Stricker G. Patients' attitudes toward gynecologic examination and to gynecologists. Med Care. 1977;15(9):987-95.
33 Petravage JB, Reynolds LF, Gardner HJ, Reading JC. Attitudes of women toward the gynecologic examination. J Fam Pract. 1979;9(6):1039-45. [pmid: 521765].
34 Kahn JA, Goodman E, Huang B, Slap GB, Emans SJ. Predictors of Papanicolaou smear return in a hospital-based adolescent and young adult clinic. Obstet Gynecol. 2003;101:490-9. [pmid: 12636952].
35 Stewart RA, Thistlethwaite J, Evans R. Pelvic examination of asymptomatic women - attitudes and clinical practice. Aust Fam Physician. 2008;37:493-6. [pmid: 18523709].
36 Amy NK, Aalborg A, Lyons P, Keranen L. Barriers to routine gynecological cancer screening for White and African-American obese women. Int J Obes (Lond). 2006;30(1):147-55. [pmid: 16231037].
37 Adams CH, Smith NJ, Wilbur DC, Grady KE. The relationship of obesity to the frequency of pelvic examinations: do physician and patient attitudes make a difference?. Women Health. 1993;20(2):45-57. [pmid: 8372479].
38 Lee TT, Westrup DA, Ruzek JI, Keller J, Weitlauf JC. Impact of clinician gender on examination anxiety among female veterans with sexual trauma: a pilot study. J Womens Health. 2007;16(9):1291-9.
39 Weitlauf JC, Finney JW, Ruzek JI, et al. Distress and pain during pelvic examinations: Effect of sexual violence. Obstet Gynecol. 2008;112:1343-50. [pmid: 19037045].
40 Weitlauf JC, Frayne SM, Finney JW, Moos RH, Jones S, Hu K, Spiegel D. Sexual violence, posttraumatic stress disorder, and the pelvic examination: how do beliefs about the safety, necessity, and utility of the examination influence patient experiences?. J Womens Health. 2010;19(7):1271-80.
41 Leeners B, Stiller R, Block E, Görres G, Imthurn B, Rath W. Effect of childhood sexual abuse on gynecologic care as an adult. Psychosomatics. 2007;48:385-93. [pmid: 17878496].
42 Robohm JS, Buttenheim M. The gynecological care experience of adult survivors of childhood sexual abuse: a preliminary investigation. Women Health. 1996;24(3):59-75. [pmid: 9046553].
43 Farley M, Golding JM, Minkoff JR. Is a history of trauma associated with a reduced likelihood of cervical cancer screening?. J Fam Pract. 2002;51(10):827-31. [pmid: 12401150].
44 Watson-Johnson LC, Townsend JS, Basile KC, Richardson LC. Cancer Screening and history of sexual violence victimization among US adults. J Womens Health. 2012;21:17-25.
45 Hilden M, Sidenius K, Langhoff-Roos J, Wijma B, Schei B. Women's experiences of the gynecologic examination: factors associated with discomfort. Acta Obstet Gynecol Scand. 2003;82:1030-6. [pmid: 14616277].
46 Lang AJ, Rodgers CS, Laffaye C, Satz LE, Dresselhaus TR, Stein MB. Sexual trauma, posttraumatic stress disorder, and health behavior. Behav Med. 2003;28(4):150-8. [pmid: 14663922].
47 Henderson JT, Harper CC, Gutin S, Saraiya M, Chapman J, Sawaya GF. Routine bimanual pelvic examinations: practices and beliefs of US obstetrician-gynecologists. Am J Obstet Gynecol. 2013;208:109.e1-7. [pmid: 23159688].
48 Centers for Disease Control and Prevention. Cervical Cancer Screening Among Women Aged 18–30 Years — United States, 2000–2010. MMWR. 2013;61(51):1038-42. [pmid: 23282861].
49 Scholes D, Stergachis A, Heidrich FE, Andrilla H, Holmes KK, Stamm WE. Prevention of pelvic inflammatory disease by screening for cervical chlamydial infection. N Engl J Med. 1996;334:1362-6. [pmid: 8614421].
50 Oakeshott P, Kerry S, Aghaizu A, et al. Randomized controlled trial of screening for Chlamydia trachomatis to prevent pelvic inflammatory disease: the POPI (prevention of pelvic infection) trial. BMJ. 2010;340:c1642. [doi: 10.1136/bmj.c1642]. [pmid: 20378636].
51 United States Preventive Services Task Force. Screening for chlamydial infection. 2007. Available from www.uspreventiveservicestaskforce.org/uspstf/uspschlm.htm. 3 September 2013.
52 Centers for Disease Control and Prevention. Chlamydia – CDC Fact Sheet. 2013. Available from http://www.cdc.gov/std/chlamydia/STDFact-Chlamydia.htm. 19 September 2013.
53 United States Preventive Services Task Force. Screening for gonorrhea. 2005. Available from www.uspreventiveservicestaskforce.org/uspstf/uspsgono.htm. 3 September 2013.
54 Schoeman SA, Stewart CMW, Booth RA, Smith SD, Wilcox MH, Wilson JD. Assessment of best single sample for finding chlamydia in women with and without symptoms: a diagnostic test study. BMJ. 2012;345:e8013. [pmid: 23236032].
55 Cook RL, Hutchison SL, Østergaard L, Braithwaite RS, Ness RB. Systematic review: noninvasive testing for Chlamydia trachomatis and Neisseria gonorrhoeae. Ann Intern Med. 2005;142(11):914-25. [pmid: 15941699].
56 Stewart CM, Schoeman SA, Booth RA, Smith SD, Wilcox MH, Wilson JD. Assessment of self taken swabs versus clinician taken swab cultures for diagnosing gonorrhoea in women: single centre, diagnostic accuracy study. BMJ. 2012;345:e8107. [pmid: 23236033].
57 Chernesky MA, Hook EW III, Martin DH, et al. Women find it easy and prefer to collect their own vaginal swabs to diagnose Chlamydia trachomatis or Neisseria gonorrhoeae infections. Sex Transm Dis. 2005;32(12):729-33. [pmid: 16314768].
58 Berwald N, Cheng S, Augenbraun M, Abu-Lawi K, Lucchesi M, Zehtabchi S. Self-administered vaginal swabs are a feasible alternative to physician-assisted cervical swabs for sexually transmitted infection screening in the emergency department. Acad Emerg Med. 2009;16:360-3. [pmid: 19220203].
59 Serlin M, Shafer MA, Tebb K, et al. What sexually transmitted disease screening method does the adolescent prefer?. Arch Pediatr Adolesc Med. 2002;156:588-91. [pmid: 12038892].
60 Henderson JT, Sawaya GF, Blum M, Stratton L, Harper CC. Pelvic examinations and access to oral hormonal contraception. Obstet Gynecol. 2010;116:1257-64. [pmid: 21099589].
61 Schwarz EB, Saint M, Gildengorin G, Weitz TA, Stewart FH, Sawaya GF. Cervical cancer screening continues to limit provision of contraception. Contraception. 2005;72(3):179-81. [pmid: 16102551].
62 Padilla LA, Radosevich DM, Milad MP. Limitations of the pelvic examination for evaluation of the female pelvic organs. Int J Gynecol Obstet. 2005;88:84-8.
63 Buys SS, Partridge E, Black A, et al., for the PLCO Project Team. Effect of screening on ovarian cancer mortality: the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Randomized Controlled Trial. JAMA. 2011;305(22):2295-303. [pmid: 21642681].
64 Menon U, Gentry-Maharaj A, Hallett R, et al. Sensitivity and specificity of multimodal and ultrasound screening for ovarian cancer, and stage distribution of detected cancers: results of the prevalence screen of the UK Collaborative Trial of Ovarian Cancer Screening (UKCTOCS). Lancet Oncol. 2009;10(4):327-40. [pmid: 19282241].
65 Baldwin LM, Trivers KF, Matthews B, et al. Vignette-based study of ovarian cancer screening: do U.S. physicians report adhering to evidence-based recommendations?. Ann Intern Med. Feb. 7. 2012;156(3):182-94. [pmid: 22312138].
66 Clarke-Pearson DL. Screening for ovarian cancer. N Engl J Med. 2009;361:170-7. [pmid: 19587342].
67 Nelson AE, Francis JE, Zorbas H, National Breast and Ovarian Cancer Centre. Population screening and early detection of ovarian cancer in asymptomatic women. Aust N Z J Obstet Gynaecol. Oct. 2009;49(5):448-50. [pmid: 19780723].
68 American College of Obstetricians and Gynecologists. The role of the obstetrician–gynecologist in the early detection of epithelial ovarian cancer. Committee Opinion No. 477. Obstet Gynecol. 2011;117:742-6. [pmid: 21343791].
69 Smith RA, Cokkinides V, Brooks D, Saslow D, Shah M, Brawley OW. Cancer Screening in the United States, 2011. A review of current American Cancer Society guidelines and issues in cancer screening. CA Cancer J Clin. 2011;61:8-30. [pmid: 21205832].
70 Gray-Swain MR, Peipert JF. Pelvic inflammatory disease in adolescents. Curr Opin Obstet Gynecol. 2006;18:503-10. [pmid: 16932044].
71 Stacey CM, Munday PE. Abdominal pain in women attending a genitourinary medicine clinic: who has PID?. Int J STD AIDS. 1994;5(5):338-42. [pmid: 7819351].
72 Munday PE. Pelvic inflammatory disease – an evidence-based approach to diagnosis. J Infect. 2000;40:31-41. [pmid: 10762109].
73 Blake DR, Fletcher K, Joshi N, Emans SJ. Identification of symptoms that indicate a pelvic examination is necessary to exclude PID in adolescent women. J Pediatr Adolesc Gynecol. 2003;16:25-30. [pmid: 12604142].
74 Soper DE. Pelvic inflammatory disease. Obstet Gynecol. 2010;116:419-28. [pmid: 20664404].
75 Centers for Disease Control and Prevention. Sexually Transmitted Diseases – Treatment Guidelines, 2010: Pelvic Inflammatory Disease. Available from: http://www.cdc.gov/std/treatment/2010/pid.htm. 14 June 2013.
76 Fisher LD, Fletcher KE, Blake DR. Can the diagnosis of pelvic inflammatory disease be excluded without a bimanual examination?. Clin Pediatr. 2004;43:153-8.
77 Klebanoff MA, Schwebke JR, Zhang J, Nansel TR, Kai-Fun Y, Andrews WW. Vulvovaginal symptoms in women with bacterial vaginosis. Obstet Gynecol. 2004;104:267-72. [pmid: 15291998].
78 Lee DM, Chen MY, Bradshaw CS, Fairley CK. Is routine vaginal examination necessary for asymptomatic women attending sexual health services?. Int J STD AIDS. 2006;17:631-2. [pmid: 16942656].
79 Singh RH, Erbelding EJ, Zenilman JM, Ghanem KG. The role of speculum and bimanual examinations when evaluating attendees at a sexually transmitted diseases clinic. Sex Transm Infect. 2007;83:206-210. [pmid: 17108005].
80 Morioka-Douglas N, Adams Hillard PJ. No Papanicolaou Tests in Women Younger Than 21 Years or After Hysterectomy for Benign Disease. JAMA Intern Med. Apr. 2013;8:1-2. [doi: 10.1001/jamainternmed.2013.316]. Epub ahead of print.
81 Berkowitz Z, Saraiya M, Sawaya GF. Cervical cancer screening intervals, 2006 to 2009: moving beyond annual testing. JAMA Intern Med. Apr. 2013;8:1-3. Epub ahead of print.
82 Stormo AR, Cooper CP, Hawkins N, Saraiya M. Physician characteristics and beliefs associated with use of pelvic examinations in asymptomatic women. Prev Med. 2012;54:415-21. [pmid: 22484240].
83 Westhoff CL, Jones HE, Guiahi M. Do new guidelines and technology make the routine pelvic examination obsolete?. J Womens Health. 2011;20:5-10.
84 Mehrota A, Zaslavsky AM, Ayanian JZ. Preventive health examinations and preventive gynecological examinations in the United States. Arch Intern Med. 2007;167(17):1876-83. [pmid: 17893309].
85 Westhoff C, Clark CJ. Benign ovarian cysts in England and Wales and in the United States. Br J Obstet Gynaecol. 1992;99(4):329-32. [pmid: 1581280].
86 LeFevre ML. Swimming Upstream-Doing Less in Health Care Is Hard. JAMA Intern Med. Published Online: April 8, 2013. [doi: 10.1001/jamainternmed.2013.535].
87 Thomson O'Brien MA, Freemantle N, Oxman AD, Wolf F, Davis DA, Herrin J. Continuing education meetings and workshops: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2001;(2):CD003030. [pmid: 11406063].
88 Grimshaw JM, Shirran L, Thomas R, et al. Changing provider behavior: an overview of systematic reviews of interventions. Med Care. Aug. 2001;39(8 Suppl 2):II2-45. [pmid: 11583120].
89 United States Preventive Services Task Force. Screening for genital herpes. 2005. Available from www.uspreventiveservicestaskforce.org/uspstf/uspsherp.htm. 3 September 2013.
90 United States Preventive Services Task Force. Screening for hepatitis B virus infection in nonpregnant adolescents and adults. 2004. Available from www.uspreventiveservicestaskforce.org/uspstf/uspshepb.htm. 3 September 2013.
91 United States Preventive Services Task Force. Screening for hepatitis B virus infection in pregnancy. 2009. Available from www.uspreventiveservicestaskforce.org/uspstf/uspshepbpg.htm. 3 September 2013.
92 United States Preventive Services Task Force. Screening for HIV. 2013. Available from www.uspreventiveservicestaskforce.org/uspstf/uspshivi.htm. 3 September 2013.
93 United States Preventive Services Task Force. Screening for syphilis infection. 2004. Available from www.uspreventiveservicestaskforce.org/uspstf/uspssyph.htm. 3 September 2013.