# METHODS

## SEARCH STRATEGY

We searched MEDLINE (OVID) for articles published from 1946 through July 2013. Our search was designed to identify studies of any design other than case series or case reports. We limited the search to studies involving human subjects published in the English language. Search terms included the following Medical Subject Headings (MeSH): Gynecological Examination, Women's Health, and Mass Screening. The full search strategy is presented in Appendix A.

To supplement our literature search, we selected nine references that we considered highly relevant to the topic (some identified in the search above, some by hand-searching). Using the “Related Citations” feature of PubMed, we identified an additional 826 English language abstracts. We also obtained additional articles from hand-searching reference lists of existing systematic reviews and pertinent studies and from suggestions by members of the Technical Expert Panel and peer reviewers.

## STUDY SELECTION

Investigators and research associates trained in the critical analysis of literature assessed for relevance the abstracts of citations identified from the literature searches. We included background papers and guidelines (published within past 5 years and of high quality), clinical trials, cohort studies, or cross-sectional studies reporting diagnostic accuracy or outcomes related to the harms and benefits of pelvic examination in asymptomatic, average risk, non-pregnant women in outpatient settings. We excluded the following:

1. Studies that did not involve asymptomatic, average-risk non-pregnant adult women,
2. Studies that did not involve an outpatient screening pelvic examination for detection of malignancy, PID, or other pathology,
3. Studies that did not report harms of the pelvic exam or of avoidance of care due to fear of the pelvic exam; morbidity or mortality from pathology detectable from the pelvic exam; false positive, false negative, or over diagnosis data from the pelvic exam, and
4. Narrative reviews, opinion Papers, letters without data, case series, or case reports.

Full text reports of studies identified as potentially eligible (or indeterminate, e.g., title only) were obtained for further review using the inclusion and exclusion criteria described above. Each article was independently reviewed by two investigators or research associates. Reasons for excluding a study at full text review were noted.

## DATA ABSTRACTION

Eligible studies were reviewed for outcomes of interest by investigators and research associates. Study characteristics, patient characteristics, and outcomes data were abstracted onto tables.

## QUALITY ASSESSMENT

We assessed the quality of studies pertaining to key question #1 using a modification of the QUality Assessment of Studies of Diagnostic Accuracy included in Systematic reviews (QUADAS) tool.9,10 The eleven elements focus on patient representativeness, quality and administration of the reference (gold standard) test, quality and administration of the index test, and data analysis with each item evaluated as “yes,” “no,” or “unclear.”

For key question #3, evidence was predominantly from survey studies. There is no established instrument for evaluating the quality of survey studies. We identified the following elements as critical factors in assessing study quality.

1. [underlined: Population]
  a. Is the survey population-based or was a convenience sample used?
  b. Was the sampling structure incorporated into the analysis (e.g., weighting the analysis for oversampling)?
2. [underlined: Survey instrument] – Was a validated questionnaire used or were the survey questions piloted with a population similar to the population of interest?
3. [underlined: Analysis of findings]
  a. Was the method for handling missing data reported and appropriate?
  b. Were the characteristics of non-responders similar to those of responders?

Response rate was also considered although a higher response rate would be expected if a convenience sample was used. We reviewed the included studies to determine whether these factors were adequately addressed and summarized our findings.

## DATA SYNTHESIS

We described and qualitatively compared the characteristics, methods, and findings of included studies. Pooled analyses of data were not possible due to limited reporting and heterogeneity of diagnostic approaches and outcomes across studies. Therefore, we summarized our findings in narrative form. We identified and highlighted findings from studies involving Veterans.

## PEER REVIEW

A draft version of this report was reviewed by technical experts, as well as VA clinical leadership. Reviewer comments were addressed and our responses may be found in Appendix B.