# INTRODUCTION

## BACKGROUND

The routine pelvic examination has been a usual part of preventive care for women for many decades. In 2008, 63.4 million pelvic examinations were performed in the United States.1 Many women and providers believe that the routine pelvic exam should be included in an annual comprehensive well-woman visit.2 The exam consists of inspection of the external genitalia, speculum examination of the vagina and cervix, bimanual examination (placement of two fingers into the vagina with simultaneous abdominal pressure provided by the examiner's other hand), and sometimes rectal or rectovaginal examination. Traditionally, the examination in the asymptomatic average risk women has been used to screen for pathology through palpation, visualization, and specimen collection.

Pathology potentially detectable on the pelvic examination includes [underlined: malignancies] (e.g., cervical, ovarian, uterine, bladder, vaginal or vulvar); [underlined: infections] (e.g., Chlamydia, gonorrhea, warts, candidiasis, bacterial vaginosis); [underlined: pelvic inflammatory disease (PID)]; or [underlined: other pathology] (e.g., atrophic vaginitis, cervical polyps, uterine prolapse, fibroids). In addition, pelvic examinations are often performed [underlined: prior to the provision of hormonal contraception].

Recent high quality evidence-based reviews and guidelines have concluded that pelvic examinations are not required for Chlamydia and gonorrhea screening3,4 or for hormonal contraception initiation5 and up-to-date evidence-based guidelines are also available for cervical cancer screening.6-8 However, we are unaware of any systematic reviews that have investigated the utility of the screening pelvic examination for detection of the other conditions in asymptomatic women.

Understanding the utility of this exam for these other conditions is important since the screening pelvic examination may cause anxiety, discomfort, and pain and may result in false positives, overdiagnosis, overtreatment, and diagnostic procedure-related harms. Moreover, fear of the exam could lead some women to avoid or postpone healthcare visits which might result in untreated sexually transmitted infections (STI), undiagnosed cervical cancer, unwanted pregnancy due to failure to obtain contraception, and/or failure to receive other preventive care such as blood pressure and cholesterol screening. Finally, conducting a pelvic examination requires additional clinician time, especially in primary care settings, and often requires the presence of a chaperone in the examination room, thus incurring resource and opportunity costs.

This systematic review was conducted to evaluate the benefits and harms of the routine screening pelvic examination in asymptomatic, average risk, non-pregnant, adult women. For cervical cancer and STI screening and for initiation of hormonal contraception we summarize the results of recent reviews and guidelines from major US healthcare organizations in the discussion section. For all other indications we performed a comprehensive search of the primary literature.

This review was nominated by the VHA Center for Health Promotion and Disease Prevention and will be used to inform VHA Clinical Preventive Services Guidelines Statements on Screening for Cervical Cancer and Ovarian Cancer.

## KEY QUESTIONS AND ANALYTIC FRAMEWORK

We developed the following key questions and an analytic framework (Figure 1) with input from a technical expert panel.

Figure 1 Analytic Framework

Key Question #1. How accurate is the screening pelvic exam for detection of malignancy (other than cervical), pelvic inflammatory disease (PID), or other benign gynecologic conditions?

Key Question #2. What are the benefits (reduced mortality and morbidity) and harms (overdiagnosis, over-treatment, diagnostic procedure-related) of the routine screening pelvic examination performed for the detection of malignancy (other than cervical), PID, or other gynecologic conditions?

Key Question #3. What are the examination-related harms and indirect benefits of performing a screening pelvic examination in asymptomatic women?

Key Question #3a. Do these harms vary by patient or provider characteristics?