# USPSTF RECOMMENDATIONS FOR SCREENING FOR SEXUALLY TRANSMITTED INFECTIONS IN WOMEN

STI, Year^a^ | Population | Recommendation | Timing of Intervention | Method of Screening | Grade^b^
Chlamydia, 2007^51^ | Sexually active, non-pregnant women age ≤ 24 and older women at increased risk | Perform Screening | Not specified | NAAT | A
Chlamydia, 2007^51^ | Pregnant women age ≤ 24 and older pregnant women at increased risk | Perform screening | First prenatal visit | NAAT | B
Chlamydia, 2007^51^ | Women age ≥ 25 whether or not they are pregnant who are at increased risk | Do not perform screening | | | C
Gonorrhea, 2005^53^ | Sexually active women (pregnant and non-pregnant) at increased risk | Perform screening | Pregnant: First prenatal visit and, if applicable, during third trimester Non-pregnant: Not specified | Vaginal culture OR NAAT OR Nucleic acid hybridization testing | B
Gonorrhea, 2005^53^ | Woman at low risk | Do not perform screening | | | D
Gonorrhea, 2005^53^ | Pregnant women not at increased risk | Insufficient evidence for or against screening | | | I
Hepatitis B, 2004^90^ | General asymptomatic population | Do not perform screening | | | D
Hepatitis B, 2009^91^ | Pregnant women | Perform screening | First prenatal visit | HBsAg testing | A
Herpes Simplex Virus, 2005^89^ | Asymptomatic pregnant women | Do not perform screening | | | D
Herpes Simplex Virus, 2005^89^ | Asymptomatic adolescents and adults | Do not perform screening | | | D
Human Immunodeficiency Virus, 2013^92^ | Persons ages 15-65 years; younger and older adults at increased risk | Perform screening | One time screening of all persons and possibly annually (highest risk) or every 3-5 years (increased risk) | Repeatedly reactive immunoassay followed by Western blot or immunofluorescent assay OR rapid testing followed by conventional testing | A
Human Immunodeficiency Virus, 2013^92^ | Pregnant women, including those who present in labor who are untreated and whose HIV status is unknown | Perform screening | During pregnancy, including women who present in labor | Repeatedly reactive immunoassay followed by Western blot or immunofluorescent assay OR rapid testing followed by conventional testing | A
Syphilis, 2004^93^ | Persons at increased risk | Perform Screening | Not specified | VDRL or RPR followed by FTA-ABS or TP-PA | A
Syphilis, 2009^93^ | Pregnant women | Perform Screening | During Pregnancy | VDRL or RPR followed by FTA-ABS or TP-PA | A
Syphilis, 2004^93^ | Persons not at increased risk | Do not perform screening | | | D

a Year of USPSTF recommendation. At the time of publication, many of these recommendations are being updated;

b Grade of USPSTF recommendation

USPSTF = United States Preventive Services Task Force; NAAT = nucleic acid amplification testing; VDRL =venereal disease research laboratory; FTA-ABS = fluorescent treponemal antibody absorption test; TP-PA = treponema pallidum particle agglutination assay; RPR = rapid plasma regain; HBsAg = Hepatitis B surface antigen