# SEARCH STRATEGIES

Database: Ovid MEDLINE(R) <1946 to July 2013>

Search Strategy:

--------------------------------------------------------------------------------

1. (pelvic exam$ or gynaecol$ exam$).mp. or exp Gynecological Examination/
2. pelvi$.mp. or exp Pelvis/
3. palpation.mp. or exp Palpation/
4. or/1–3
5. women$ health.mp. or exp Women's Health/
6. exp Female/
7. 5 or 6
8. (asymptom$ or routin$ or screen$ or mandat$).mp. or exp Mass Screening/
9. 4 and 7 and 8
10. ovar$ cancer.mp. or exp Ovarian Neoplasms/
11. exp Uterine Cervical Neoplasms/ or uter$ cancer.mp.
12. adnexa uteri.mp. or exp Adnexa Uteri/
13. vagin$ smear$.mp.
14. vagin$ disease$.mp. or exp Vaginal Diseases/
15. contracept$.mp. or exp Contraception/
16. contraceptives.mp. or exp Contraceptive Agents/
17. chlamydia.mp. or exp Chlamydia Infections/ or exp Chlamydia/
18. std.mp. or exp Sexually Transmitted Diseases/
19. or/10–18
20. 9 and 19
21. limit 20 to English language
22. limit 21 to humans
23. case report.mp. or exp Case Reports/
24. case series.mp.
25. 23 or 24
26. 22 not 25
27. prostate.mp. or exp Prostate/
28. 26 not 27