# SUMMARY AND DISCUSSION

Our evidence synthesis identified 39 articles encompassing 25 unique studies of IPV prevalence among U.S. active duty and Veteran populations. Of these, 13 studies (25 articles12,13,15,18,39-59) evaluated prevalence among active duty servicemembers, and 12 studies (14 articles7,27,60-71) among Veterans. Estimating the pooled prevalence of IPV was challenging due to variations in definitions of IPV, measurement instruments used to detect IPV, timing of IPV reports (e.g., 12-month, lifetime), and limitations in available population data across studies. These factors likely contributed to the underlying heterogeneity we found across studies as well as in our summary estimates. However, our findings provide support that IPV is a prevalent health concern among active duty servicemembers and Veterans.

We also identified six SRs that evaluated interventions aimed at decreasing exposure to IPV.2,73-77 None of these SRs assessed primary IPV prevention strategies; all summarized literature on secondary prevention strategies such as screening for IPV. Overall, screening in health care settings increases identification of IPV victimization and appears to be feasible and acceptable. Screening alone, however, does not decrease rates of IPV victimization. Other secondary prevention strategies (behavioral interventions, advocacy interventions) provide insufficient evidence to demonstrate significant changes in IPV or IPV-related mental or physical harms. In the next section, we summarize the main findings by KQ.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### KQ 1 Prevalence of IPV

#### IPV Among Active Duty Servicemembers

We identified 13 studies that assessed IPV prevalence among U.S. active duty populations.12,13,18,39-46,56,59 Of these, 10 assessed perpetration outcomes12,18,40,42-46,56,59 and 10 assessed victimization outcomes.13,18,39-42,45,46,56,59 The most common metric of IPV across studies was prior exposure to physical violence in last year; thus, we used this outcome to summarize rates.

We were able to pool 6 studies12,15,42,46,48,59 of IPV perpetration in the last year. Pooled estimates yielded a weighted estimated mean prevalence rate of 22 percent (95% CI, 17% to 27%) with significant heterogeneity (I^2^>90%). Influence analysis yielded a range of 18 percent to 23 percent for IPV perpetration among active duty servicemembers.

We identified 4 studies47,48,54,59 that assessed victimization by physical IPV among active duty servicemembers and that met criteria for a meta-analysis. The 12-month weighted estimated mean prevalence rate of physical IPV victimization of active duty servicemembers yielded a point estimate of 30 percent (95% CI, 17% to 43%) significant heterogeneity (I^2^>90%). Influence analysis yielded a range of 25 percent to 33 percent of exposure to IPV victimization of active duty servicemembers.

We conducted subgroup analyses by (1) era of cohort recruitment (pre-2001 versus post-2001), (2) IPV severity, and (3) gender to probe for group differences. All analyses showed group differences, but each pooled subgroup estimate also had high heterogeneity. Variability in prevalence is likely due to a combination of factors, including the small number of pooled studies.

#### IPV Among Veterans

We identified 12 studies that assessed IPV prevalence among Veterans.7,27,60,61,63-70 Eight of the 12 studies comprised clinical samples of VA users. In total, 5 studies assessed perpetration7,27,61 and 8 studies assessed victimization.60,63-70 Populations and outcomes were too heterogeneous to meta-analyze across the perpetration studies. Samples comprised specialized populations (e.g., Veterans seeking relationship help, newly returning OEF/OIF Veterans referred to behavioral health) with a high mental health burden, or were gender-specific samples. Moreover, IPV perpetration was defined inconsistently across studies, ranging from physical abuse as measured on the CTS to any form of domestic abuse. Thus, the prevalence of IPV perpetration within the last year ranged considerably (15% to 60%) across these five studies.

Of the eight victimization studies, two reported on sexual violence only and none provided estimates for male Veterans. The most common estimate of exposure to IPV was lifetime abuse; thus, we used lifetime estimates as the main outcome to syntheses the data. Four of the eight studies were amenable to meta-analysis (n= 2453).60,63,64,68 The pooled lifetime weighted estimated mean prevalence rate of physical IPV victimization among women Veterans yielded a point estimate of 35 percent (95% CI, 25% to 47%). Influence analysis yielded a range of 30 percent to 41 percent victimization of women Veterans. The overall prevalence estimate had high heterogeneity, but limited data precluded moderation analysis to query for subgroup differences. Two studies reported on also reported on the on the prevalence of IPV victimization in the last year among women Veterans. Prevalence estimates in these two studies ranged from 7 to 12%.

Table 7 summarizes the prevalence of IPV for both Veteran and active duty populations.

Table 7 Summary of IPV prevalence

Population | IPV Perpetration (12-month) | IPV Victimization (12-month) | IPV Victimization (lifetime)
Active duty | 19% | 23% | ---
Veterans | 15% to 60% | 7% to 12% (women only) | 35% (women only)

### KQ 2 Intervention Strategies for IPV

We identified four good-quality2,73-75 and two fair-quality76,77 SRs that evaluated interventions aimed at decreasing exposure to IPV and its associated harms. We identified no SRs that evaluated primary prevention interventions; all six SRs assessed secondary prevention interventions. Most focused on reducing victimization; only one study focused on perpetration. Four2,73,76,77 of the six SRs assessed IPV screening interventions, three2,75,77 assessed behavioral interventions, and one74 assessed advocacy interventions. Below we summarize the results of these SRs and the strength of the evidence for these interventions.

#### Screening for IPV Victimization

Screening women can accurately identify those who have been exposed to IPV,2 can increase disclosure of IPV victimization,2,76 and incurs few adverse effects.2,73 Specific results, however, vary by screening tool, populations, and setting. Repeated screenings during pregnancy increase identification of IPV victimization.77 Screening interventions that included institutional support, ongoing training, and immediate access to referral services significantly increase rates of IPV screening, disclosure, and identification compared with screening interventions using a less comprehensive approach.76 In an emergency room environment, computerized IPV screening had high feasibility and acceptability.73 Screening interventions may decrease recurrence of IPV and physical and mental harms associated with IPV, but the evidence is limited (one RCT2). Overall based on multiple studies, there is high strength of evidence that IPV screening can detect women exposed to IPV. There is insufficient to low strength of evidence that IPV screening alone influences all other outcomes (i.e., rates of IPV, IPV-related physical or mental harms, referrals and treatment for IPV, mortality).

#### Behavioral Interventions

We identified three SRs2,75,77 that evaluated behavioral interventions. Two of these synthesized the evidence on behavioral interventions among women exposed to IPV, and one75 focused on male perpetrators of IPV. The SR that focused on perpetration synthesized the evidence on CBT for men who abuse their female partners. Compared with nonintervention controls, CBT for men who physically abuse their female partners reduced rates of IPV but did not demonstrate a statistically significant improvement across four RCTs (RR 0.86; 95% CI, 0.54 to 1.38). Overall, the evidence around interventions focusing on reducing and treating perpetration is limited; the strength of evidence is low due to imprecise estimates (wide confidence internals) and inconsistent results across the four included studies.

For the two SRs that focused on women victims of IPV, one77 focused on pregnant women and identified four studies, and the other SR2 identified six RCTs, three of which were conducted in pregnant or postpartum women. Some studies were included in both SRs, thus there were only five unique studies among pregnant or postpartum women across the two SRs. The behavioral interventions tested in these studies were heterogonous and included home visitation, nurse management, unspecified counseling interventions plus resource card, or mentor support. Among pregnant and postpartum women, behavioral interventions that include counseling reduced IPV2,77 and improved birth outcomes.2 However, strength of evidence was graded as insufficient. Across these SRs, there were few studies identified, and the types of behavioral interventions were quite different from each other, which hampered drawing conclusions across this category of interventions.

#### Advocacy Interventions

We identified one SR74 that assessed 10 advocacy intervention studies. Again, intervention approaches were heterogeneous and included education and support to enhance provision of legal, housing, and financial advice; promote access and use of community shelters, emergency housing, and psychological interventions; and provide safety planning. Intensive advocacy interventions (>12 hours in duration) for women recruited in domestic violence shelters reduced physical abuse 12 to 24 months postintervention (OR 0.43; 95% CI, 0.43 to 0.83) but not in the year immediately following intervention. Brief interventions (<12 hours) increased the use of safety behaviors. No significant effects were found for mental harm (e.g., PTSD, depression) or use of IPV-related services. There is low strength of evidence that intensive advocacy interventions reduced IPV; results were consistent, but confidence internals were wide.

## CLINICAL AND POLICY IMPLICATIONS

Compared with population-based studies conducted in samples not selected for active duty or Veteran status, we report higher rates of 12-month IPV perpetration and victimization among active duty women servicemembers; considerably higher 12-month IPV victimization rates for active duty men; and comparable rates of both 12-month IPV perpetration among active duty men and lifetime IPV victimization among Veteran women. We also found that the 12-month victimization rate is higher among active duty men than active duty women—a pattern that has also been observed in civilian studies (Table 8).79 Some differences between civilian and active duty or Veteran populations can be attributed to dissimilar distribution of population characteristics between the two groups (e.g., age distribution, greater proportion of African Americans and Hispanics among active duty and Veteran populations). However, factors unique to military life such as military deployments that result in family separation and reintegration issues,7 and combat-related health issues (e.g., PTSD, head injuries) likely contribute to relationship stress and IPV among active duty servicemembers, Veterans, and their intimate partners.9-12

Table 8 Comparison of IPV prevalence in active duty servicemembers, Veteran, and community populations

Population | IPV Perpetration (12-month) | | IPV Victimization (12-month) | | IPV Victimization (Lifetime)
Population | Women | Men | Women | Men | Women | Men
Active duty | 29% | 18% | 26% | 31% | — | —
Veterans | 22%^a^ | 15% to 60%^b^ | 7 to 12% | — | 35% | —
Community^c^ | 16% | 15% | 6% | 5% | 36% | 29%

a One study only.70

b Some Veteran studies of IPV perpetration included women, but the majority were men.

c Community estimates for perpetration are from Field et al., 2003,^69^ and for victimization from Black et al., 2011.^1^

Evidence from our synthesis of SRs assessing IPV interventions demonstrates that standardized IPV screening interventions in a health care setting increases identification of IPV victimization. Moreover, Nelson et al.2 found minimal adverse effects and low levels of harm related to IPV screening for women receiving health care services. Coupled with the prevalence of IPV we report here, these findings support the need to consider adopting standardized IPV screening for use in the VA. However, our review also highlights the need to take a comprehensive approach to implementing such screening programs in the VA.

Our meta-synthesis finds that multicomponent screening interventions that include institutional support, use effective screening protocols, thorough initial and ongoing training of providers, and immediate access to referral services increase provider use of screening, patient disclosure, and, ultimately, identification of IPV. This finding suggests that establishing a screening program without building provider self-efficacy to screen and establishing sufficient support for referral and treatment mechanism will undermine the effectiveness of IPV screening programs. Our synthesis of the SR literature found some evidence to support behavioral counseling and advocacy interventions for women who screen positive for IPV; however, the evidence was often inconsistent—likely due to the wide variability in strategy, content, and intensity.

While primary care physicians and mental health clinicians may be ideally positioned to implement screening, successful IPV screening programs must also consider educating and enlisting the services of the entire health care team, including other providers, nurses, and social workers, to create a seamless system from screening to timely referral to appropriate services. The development of resource toolkits for clinicians that include (1) appropriate community or Veteran resources, (2) information on local and state laws regarding IPV, and (3) availability of counseling, legal, and advocacy referrals could help overcome some of the provider and institutional barriers to providing IPV screening throughout the VA healthcare system. Due to the sensitive nature of IPV screening, cultural sensitivity and confidentiality concerns would also need to be considered in the development of any IPV screening program. The Institute of Medicine recommends that women be screened about current and past violence and abuse in a culturally sensitive and supportive manner,80 and assuring patient confidentiality and safety is paramount.

Another consideration when planning an IPV screening program is how often to make assessments. Most screening tools were designed to detect IPV in the previous year. Thus, an annual interval may be optimal. Any screening program will need to consider the optimal use of provider and staff resources in addition to the benefit from screening for IPV victimization obtained from repeated followup screenings.

While the evidence we report here on effectiveness of screening for IPV was conducted among female populations, we also report considerable rates of IPV victimization among male populations. The U.S. armed services and the Veteran healthcare system currently remain largely male in population despite the growing number of female servicemembers and Veterans. The VHA provides medical and mental health care for an estimated 8.6 million Veterans each year, and only an estimated 6 percent to 8 percent of the Veterans cared for are women.81 Indeed, our data suggest that the overall rates of IPV victimization among male active duty servicemembers are at least equal to if not higher than rates of overall IPV victimization among female active duty servicemembers. However, women are more likely to be injured or murdered as a result of IPV.82-84 This fact raises the question of whether IPV screening programs in the VA should be extended to men as well. In constructing a comprehensive national program to address IPV, consideration should be given to the prevalence of IPV victimization and perpetration, the effectiveness of interventions to decrease exposure to IPV and decrease the associated mental and physical harms, the potential benefits and harms of screening, and if universal or women-only screening should be adopted.

### Guidelines

Currently, a number of organizations recommend some form of screening to detect IPV victimization. Most guidelines focus screening recommendations among women. The American Congress of Obstetricians and Gynecologists recommends that physicians screen all women for IPV victimization at periodic intervals during family planning, pregnancy, and annual examinations.78,85 Similarly, the Affordable Care Act recommends IPV screening and counseling as a core part of women's preventive health visits, and the Institute of Medicine recommends universal screening and counseling of all women for interpersonal and domestic violence.80

The American Medical Association (AMA) makes a broader recommendation regarding all patients and thereby actively includes men in addition to women. In a position statement, the AMA broadly encourages physicians to routinely inquire about the family violence histories of their male and female patients while being alert to men presenting with injuries suffered as a result of IPV because these men may require intervention as either victims or abusers themselves. The AMA recommends identifying patients currently experiencing abuse or threats of IPV to discuss safety issues with the patient before leaving the office, to develop a safety or exit plan, and to refer patients to appropriate medical or health care professionals or community-based trauma resources as soon as possible.86

The USPSTF has recently updated its recommendations regarding IPV victimization screening in women and recommends screening women of childbearing age (defined as 14 to 46 years of age) for IPV. In addition, the USPSTF recommends providing services or interventions to women who screen positive for IPV.78 Adopting the USPSTF recommendations would be timely for the VHA because over the past decade, the number of women Veterans using the VHA has nearly doubled, and compared with men, women were, on average, substantially younger: 42 percent of women and 12 percent of men were younger than 45 years of age or of childbearing age.81

Our results broadly support these recommendations; however, our review highlights the need for developing an a priori detailed plan of action for treatment and followup of positive IPV screening results.

## APPLICABILITY

Our results on prevalence are highly applicable to Veteran populations seeking care through the VA healthcare system; these studies were conducted in Veterans or among potential future Veterans (i.e., active duty servicemembers). Also of the 12 studies conducted among Veterans, 8 were conducted among populations comprising exclusively VA users. For our pooled analyses, we included only studies conducted in broad populations and used the most comparable estimate of IPV collected across studies: physical violence. However, variability still existed in how IPV was defined and measured, likely contributing to the heterogeneity we report across studies and in pooled estimates.

Results of our synthesis of the SR literature for IPV interventions also are likely to apply to Veterans; however, the positive effects of RCTs do not always translate into clinical practice. RCTs usually have tightly controlled eligibility criteria; thus the characteristics of patients in RCTs may vary from the characteristics of patients seen at VA medical centers. For example, there are higher rates of PTSD, depression, and traumatic brain injuries in VA populations compared with civilian populations; these factors may complicate implementation of IPV screening and treatment programs. Also, interventionists in studies may receive specialized training and resources that may be difficult to replicate in the typical clinical practice. Last, patients in RCTs tend to be more adherent to interventions. Across all studies in the included SRs, only one intervention study was conducted in a VA setting.

## STRENGTHS AND LIMITATIONS

Our study has a number of strengths, including a protocol-driven review, a comprehensive search, and a careful quality assessment. Also, our meta-analysis took advantage of both direct (estimated from within the same study) and indirect (estimated from across different studies) when assessing key subgroups of gender and race. Another strength is the opportunity to meta-synthesize the evidence on IPV interventions from existing SRs in order to triangulate the overarching evidence across a wide body of literature, settings, and intervention approaches.

Our report, and the literature, also had limitations. Though we were able to conduct meta-analysis and subgroup analysis for some IPV prevalence rates, all estimates demonstrated significant heterogeneity. Thus, variability in prevalence is likely due to a combination of factors, and the limited number of studies precluded meta-regression. Also, we identified only five studies that assessed IPV perpetration among Veterans. However, each of these studies was conducted in highly selective populations (e.g., WWII prisoners of war, populations seeking relationship help), making meta-analysis imprudent and comparisons to broader Veteran populations impossible. We also did not identify any studies that assessed prevalence of IPV victimization among male Veterans, thus, we were not able to provide estimates for this population and behavior. Lastly, only three studies of IPV among Veterans were conducted among national samples; thus, our results specific to Veterans are likely more applicable to VA user than to all Veterans. More studies should be conducted among nationally representative samples of Veterans. Our meta-synthesis of the evidence on IPV interventions also has some limitations. We were able to include only intervention approaches with peer-reviewed evidence syntheses. Thus, emerging intervention approaches were likely not included if they did not have a peer-reviewed evidence synthesis.

## RECOMMENDATIONS FOR FUTURE RESEARCH

We used the framework recommended by Robinson et al.87 to identify gaps in evidence and classify why these gaps exist (Table 9). This approach considers PICOTS (population, intervention, comparator, outcomes, timing, and setting) to identify gaps and classifies them as due to (1) insufficient or imprecise information, (2) biased information, (3) inconsistency or unknown consistency, and (4) not the right information. VA and other healthcare systems should consider their clinical and policy needs when deciding whether to invest in research to address gaps in evidence. Specific research questions can be evaluated quantitatively, using value-of-information analysis, which uses Bayesian methods to estimate the potential benefits of gathering further information through research.88

Table 9 Evidence gaps and future research

Evidence Gap | Reason | Type of Studies to Consider
Limited to no evidence for these populations and behaviors:; - Male Veteran IPV perpetration; - Male Veteran IPV victimization; - Female Veteran IPV victimization in last year; - Nationally representative samples of Veterans for both perpetration and victimization | Insufficient information | High-quality cross-sectional studies in broad populations
Studies that address primary prevention of IPV | Insufficient information | RCTs Observational comparative effectiveness studies
Effectiveness of screening techniques to identify males with exposure to IPV victimization | Insufficient information | Studies of diagnostic accuracy RCTs Observational comparative effectiveness studies
Effectiveness of screening techniques to identify perpetrators of current or past IPV | Insufficient information | Studies of diagnostic accuracy RCTs
Studies on interventions to reduce IPV in screen-detected populations | Insufficient information | RCTs Observational comparative effectiveness studies

## CONCLUSION

Our review highlights that IPV victimization and perpetration are prevalent among active duty servicemembers and Veterans. Overall, IPV screening interventions for women in health care settings increase identification of victimization and appear to be feasible and acceptable. Screening programs are maximized when adequate support for clinicians and screen-detected women are provided. Other secondary prevention interventions provide insufficient evidence to demonstrate significant changes in IPV or IPV-related mental or physical harms. Our review points to gaps in the existing evidence. No identified studies reported on IPV victimization among male Veterans; however, we report high rates of victimization among male active duty servicemembers. Thus, it is likely that male Veterans would also have elevated rates of IPV victimization. Only three studies of IPV among Veterans were conducted among national samples. Many Veteran studies were conducted in specialty mental health clinics or highly selected populations. Future research on IPV should be conducted among nationally representative samples of Veterans. Moreover, we identified no SRs of primary IPV prevention strategies; all SRs summarized literature on secondary prevention strategies (e.g., IPV screening). These findings demonstrate gaps in the evidence; future studies are needed. However, current evidence suggests that screening women for IPV can identify women who have been exposed to IPV. In the absence of strong evidence to support any single strategy to reduce risks associated with IPV in screen-detected populations, behavioral and advocacy interventions should be considered as adjuncts to IPV screening programs because they have some partial impact on IPV-related mental or physical health outcomes and show limited evidence that they are associated with harms.