# RESULTS

## LITERATURE SEARCH

The flow of articles through the literature search and screening process is illustrated in Figure 2 (IPV prevalence) and Figure 3 (IPV interventions). We identified 654 unique citations from a combined search MEDLINE via PubMed (n=123), CINAHL (n=42), PsycINFO (n=59), and Social Sciences Citation Index (SSCI), a subset of the Web of Science database (n=430), from inception through December 2012. All databases except SSCI were updated in June 2013. Manual searching of included study bibliographies and review articles identified 15 more citations for a total of 669 citations. After applying inclusion and exclusion criteria at the title-and-abstract level, 106 full-text articles were retrieved for further evaluation. Of these, 67 were excluded at the full-text screening stage, leaving 39 articles representing 25 unique primary studies and 14 companion articles for data abstraction.

Figure 2 Literature flow for IPV prevalence studies (KQ 1)

* See glossary for definition of companion articles.

Abbreviations: KQ=key question

Figure 3 Literature flow for IPV systematic reviews (KQ 2)

For intervention strategies (KQ 2), we searched MEDLINE via PubMed (n=1404), EMBASE (n=562), CINAHL (n=254), PsycINFO (n=37), and the Cochrane Database of Systematic Reviews (n=229) for peer-reviewed SRs from January 2007 through December 2012; an updated search was conducted in March 2013 for a total of 2486 articles. After applying inclusion and exclusion criteria at the title-and-abstract level, 96 full-text SRs were retrieved for further evaluation. Of these, 90 were excluded at the full-text screening stage, leaving 6 SRs for data abstraction.

## KEY QUESTION 1 What is the prevalence of intimate partner violence among Veterans and active duty servicemembers, and does the prevalence vary by cohort (e.g., Vietnam era, OEF/OIF/OND era), gender, or race?

Key Points
- The overall prevalence of 12-month IPV perpetration among active duty servicemembers was 22 percent, and victimization was 30 percent. Both estimates had high heterogeneity.
- Among active duty populations, moderator analysis by era of service, IPV severity, and gender all showed group differences, but each pooled subgroup estimate also had high heterogeneity. Thus, the variability in prevalence is likely due to a combination of factors.
- Of the 12 studies that assessed IPV among Veterans, only 5 assessed IPV perpetration. Populations and outcomes were too heterogeneous to meta-analyze. The prevalence of IPV perpetration within the last year ranged considerably (15% to 60%). However, samples consisted of specialized populations (e.g., Veterans seeking relationship help, newly returning OEF/OIF Veterans referred to behavioral health) with a high mental health burden, or were gender-specific samples.
- Only eight studies assessed IPV victimization among Veterans. None of these studies provided estimates for male Veterans, and only two provided an estimate of 12-month prevalence; estimates ranged from 7 percent to 12 percent. Among women Veterans, the prevalence of lifetime IPV victimization was 35 percent. The estimate had high heterogeneity, but limited data precluded moderator analysis to query for subgroup differences.

### Description of Included Studies

We identified 25 primary studies (with 14 linked companion articles, for a total of 39) for IPV prevalence (details shown in Table 3). Thirteen of these (encompassing 25 articles12,13,15,18,39-59) evaluated IPV prevalence among U.S. active duty servicemembers (n=88,568). Twelve (encompassing 14 articles7,27,60-71) evaluated IPV prevalence among Veterans (n=25,497). Of the 12 Veteran studies, 10 were conducted among populations exclusively comprising VA users (i.e., clinical samples).

Table 3 Study characteristics of the IPV prevalence studies

Primary Article (Companion Article) | Geographic Location Setting Recruitment Total N | Population Age in Years (SD) % Female % White | Outcomes Timing of Outcome | Measurement Tool Type of Violence | Included in Meta-analysis? If No, Reason for Exclusion | Quality
Bohannon, 1995^18^ | Southeastern US General internal medicine Not reported N=188 | Active duty 29.2 (NR) 50% 73.4% | Perpetration and victimization 12 months | CTS Physical | No Study assessed couples but did not report separate estimates for active duty participants | Fair
Campbell, 2003^13^ (O'Campo, 2006^55^) | Washington, DC General internal medicine Jan 1998–Oct 2000 N=616 | Active duty Categorical 100% 75.6% | Victimization Lifetime | AAS Psychological, emotional, physical, sexual, stalking | No No 12-month outcome data | Fair
Campbell, 2005^66^ (Campbell, 2008^71^) | Midwestern US General internal medicine Not reported N=268 | Veteran Majority >45 100% 0% | Victimization Lifetime | SES Sexual | No Reported sexual violence only | Fair
Caralis, 1997^68^ | Miami, FL General internal medicine Jun 1995–Aug1995 N=406 | Veteran 50.4 (16) 100% 57% | Victimization 12 months, lifetime | AAS Psychological, emotional, physical, sexual | Yes | Fair
Coyle, 1996^64^ | Baltimore, MD General internal medicine Jul 1994–Dec 1994 N=429 | Veteran 42.3 (NR) 100% 0% | Victimization Lifetime | STS Physical, sexual | Yes | Poor
Dichter, 2011^60^ | BRFSS General internal medicine 2006 N=21,162 | Veteran Categorical 100% 67.8% | Victimization Lifetime | STS Physical, sexual | Yes | Poor
Dobie, 2004^63^ | Seattle, WA General internal medicine Oct 1996–Jan 1998 N=1206 | Veteran 46.0 (15.0) 100% 73.0% | Victimization Lifetime | STS Physical | Yes | Fair
Dutra, 2012 70 | USA General internal medicine 1984-1988 N=178 | Veteran 24.8 (5.0) 50% 95.6% | Perpetration and Victimization 12 months | CTS Physical, psychological | No Too few studies to preform meta-analysis | Fair
Fonseca, 2006^12^ (Schmaling, 2011^52^) | Fort Bliss, TX General internal medicine Mar 2003–Nov 2003 N=2926 | Active duty 35.0 (8.86) 9.1% 64.3% | Perpetration 12 months | CTS Physical | Yes | Good
Forgey, 2006^56^ (Forgey, 2010^50^) | Not reported General internal medicine Jul 2001–Sep 2001 N=248 | Active duty 29.8 (7.0) 100% 37.1% | Perpetration and victimization 12 months | CTS Psychological, emotional, physical, sexual | Yes Gender subgroup meta-analysis only | Fair
Heyman, 1999^45^ (Newby, 2003;57 McCarroll, 2000;15 McCarroll, 2010^58^) | Army, US General internal medicine 1990–1994 N=33,762 | Active duty Categorical 8.2% 58.6% | Perpetration and victimization 12 months | CTS Physical | Yes | Good
Luterek, 2011^65^ | Seattle, WA Mental health Not reported N=208 | Veteran 51.1 (NR) 50% 75% | Victimization Lifetime | TLEQ Physical | No Not broad population (PTSD and other mental health clinics) | Fair
Lutgendorf, 2009^41^ | Portsmouth, VA OB-GYN Jan 2007–Mar 2008 N=1104 | Active duty Median=24 100% 56.1% | Victimization 12 months, lifetime | AAS Psychological, emotional, physical, sexual | No Not broad population (pregnant women) | Fair
Lutgendorf, 2012^39^ | Portsmouth, VA OB-GYN Oct 2008–Jun 2009 N=461 | Active duty Median=24 100% 54.7% | Victimization 12 months, lifetime | AAS Psychological, emotional, physical, sexual | No Not broad population (pregnant women) | Fair
McCarroll, 2003^44^ | Not reported General internal medicine Jun 1999–Jun 1999 N=1025 | Active duty 28.44 (NR) 0% 57.0% | Perpetration Lifetime | CTS Physical | No No 12-month outcome data | Good
Merrill, 1998 59 | Orlando, FL General internal medicine NR N=2987 | Active duty 20.3 (2.5) 52.2% 69.7% | Perpetration and victimization 12 months | CTS Physical, psychological | Yes | Fair
Merrill, 2005^42^ (Crouch, 2009;54 Stander, 2011^53^) | Greater Lakes, IL General internal medicine Jun 1996–June 1997 N=963 | Active duty 19.81 (2.79) 56.3% 57.0% | Perpetration and victimization 12 months | CTS Physical | Yes | Fair
Newby, 2005^43^ | Not reported General internal medicine May 2000–Aug 2000 N=896 | Active duty 31.0 (NR) 100% 70.0% | Perpetration 12–15 months, lifetime | CTS Physical | Yes Gender subgroup meta-analysis only | Fair
O'Donnell, 2006^27^ | California General internal medicine Not reported N=331 | Veteran 80 (3.2) 0% NR | Perpetration 12 months | CTS Physical | No Not broad population (WWII prisoners of war) | Poor
Rosen, 2002^49^ (Rosen, 2002;47 Rosen, 2002;46 Rosen, 2003^51^) | USARAK, Alaska General internal medicine Jun 1998–Sep 1998 N=648 | Active duty Categorical 0% 58.2% | Perpetration 12 months | CTS Psychological, emotional, physical | Yes | Good
Sadler, 2003^67^ | DVA WHCCR General internal medicine Sep 1996–May1997 N=506 | Veteran 40 (9) 100% 73.9% | Victimization Not reported | STS Sexual | No Reported only sexual violence during service | Fair
Sayers, 2009^7^ | Philadelphia, PA Mental health April 2006–Aug 2007 N=199 | Veteran 32.7 (9.1) 10.6% 53.3% | Perpetration 6 months | STS Psychological, emotional, physical | No Not broad population (returning OEF/OIF Veterans referred for behavioral health for evaluation) | Poor
Slep, 2010^40^ (Foran, 2011^48^) | Air Force, International General internal medicine Apr 2006–Jun 2006 N=42,744 | Active duty Age not reported 19.0% 74.1% | Perpetration and victimization 12 months | STS Psychological, emotional, physical, stalking | Yes | Good
Taft, 2009 69 | Boston, MA Mental health Jan 2003–Jan 2008 N=236 | Veteran NR (NR) 0% NR | Perpetration 12 months | CTS Physical, psychological | No Not broad population (combat-exposed Veterans seeking PTSD evaluation and/or treatment) | Fair
Teten, 2009^61^ (Sherman, 2006^62^) | Houston, TX Mental health Sep 1997–Nov 2003 N=368 | Veteran 47.5 (NR) 50% 87.5% | Perpetration 12 months | CTS Physical, sexual | No Not broad population (couples seeking family therapy for relationship issues) | Fair

a Determination of the outcome was from the perspective of the Veteran. For example, a study of IPV among civilian spouses of active duty servicemembers would be coded as a perpetration outcome.

Abbreviations: AAS=Abuse Assessment Screen; BRFSS=Behavioral Risk Factor Surveillance System; CTS=Conflict Tactics Scale; DVA WHCCR=Department of Veterans Affairs Women's Health Care Centers Registries; NR=not reported; OB-GYN=obstetrics and gynecology; OEF=Operation Enduring Freedom; OIF=Operation Iraqi Freedom; SD=standard deviation; STS=Sexual Trauma Scale; TLEQ=Traumatic Life Events Questionnaire; USARAK=United States Army in Alaska

Most of the military studies were assembled from surveys conducted on bases and consisted of broad populations of soldiers and, in some instances, their spousal dependents. The majority of participants in the active duty studies were male and white, with a median age of 28. In contrast, the majority of Veteran studies were conducted among populations exclusively comprising VA users (i.e., clinical samples). Moreover, many Veteran studies were conducted in specialized populations; four7,61,65,69 were conducted through mental health clinics, and one27 focused on IPV among World War II prisoners of war. The majority of participants in the Veteran studies were women and white, with a median age of 46. Most of the 25 studies were rated fair quality; however, a quarter of the Veteran studies were rated poor quality compared with none of the active duty studies. While a variety of measurement tools were used to assess IPV, the most common tool was self-reported via the Conflict Tactics Scale (CTS). Details of the participants are shown in Table 4.

Table 4 Participant characteristics of the IPV prevalence studies

Study Characteristic | Active Duty | Veteran
N studies (n participants) | 13 (88,568) | 12 (25,497)
Age: median (range) | 28.44 (19.8–35)^a^ | 45.5 (24.8–80)^b^
Sex: n (%)^c^
Female | 16,590 (18.7%) | 24,375 (95.6%)
Male | 69,247 (78.2%) | 1047 (4.1%)
Race: n (%)
Black | 15,975 (18.0%) | 392 (1.5%)
Hispanic | 5337 (6.0%) | 80 (0.31%)
White | 59,141 (66.8%) | 16,597 (65.1%)
Other | 5336 (6.0%) | 6921 (27.1%)
Not reported | 2779 (3.1%) | 1364 (5.3%)
Setting: n studies (% of studies)
General medical | 11 (84.6%) | 8 (66.7%)
Mental health | 0 | 4 (33.3%)
Obstetrics-gynecology | 2 (15.4%) | 0
IPV measurement tool: n studies (% of studies)
AAS | 3 (23.1%) | 1 (8.3%)
CTS | 9 (69.2%) | 4 (33.3%)
SES | 0 | 1 (8.3%)
TLEQ | 0 | 1 (8.3%)
Study-specific | 1 (7.7%) | 5 (41.7%)
Study quality: n (%)
Good | 5 (38.5%) | 1 (8.3%)
Fair | 8 (61.5%) | 8 (66.7%)
Poor | 0 | 3 (25%)

a N=grand mean of 10 means and medians that were reported or could be calculated; NR=1.

b N=grand mean of 12 means and medians that were reported or could be calculated; NR=2.

c Missing data=2731.

Abbreviations: AAS=Abuse Assessment Screen; CTS=Conflict Tactics Scale; IPV=intimate partner violence; SES=Sexual Experiences Survey; TLEQ=Traumatic Life Events Questionnaire

#### Prevalence of IPV Among Active Duty Servicemembers

We identified 13 studies that assessed IPV prevalence among active duty populations.12,13,18,39-46,56,59 Of these, 10 assessed IPV perpetration12,18,40,42-46,56,59 and 10 assessed IPV victimization.13,18,39-42,45,46,56,59 All but two studies13,44 assessed prevalence in the last year. Two39,41 were conducted among patients seeking prenatal care. One18 assessed IPV among couples but did not report separate estimates for active duty participants. Because of the unique design characteristics of these studies, they were excluded from analyses for IPV prevalence among active duty servicemembers. Two studies were conducted among gender specific populations (e.g., male soldiers only);43,56 these two studies were included in the gender subgroup meta-analysis only.

For the purpose of this review, IPV perpetration is defined as committing emotional, physical, or sexual abuse on an intimate partner (e.g., girlfriend, spouse). IPV victimization is defined as the experience of emotional, physical, or sexual abuse by an intimate partner. Below we report the results for perpetration and victimization separately and focus on the most common metric of IPV reported across included studies: 12-month physical abuse. When studies reported multiple estimates of IPV (e.g., any IPV vs. severe IPV only), we used the more inclusive prevalence estimate.

##### IPV Perpetration

We identified 6 studies that met criteria for a random-effects meta-analysis assessing perpetration of physical IPV among active duty servicemembers (n=65,366).12,15,42,47,48,59 Figure 4 shows the forest plot of the 12-month weighted estimated mean prevalence rate of physical IPV perpetration. Pooled estimates across the 6 studies yielded a point estimate of 22 percent (95% CI, 17% to 27%); this estimate had significant heterogeneity (I^2^=100%).

Figure 4 Prevalence of physical IPV perpetration among active duty servicemembers by era of service

Estimates varied by era of service. For servicemembers enrolled before 2001, the weighted estimated mean prevalence was 26 percent (n=19,781 from 4 studies; 95% CI, 14% to 38%), and for those enrolled from 2001 forward, the prevalence was 14% (n=45,585 from 2 studies; 95% CI, 12% to 17%). Both subgroups exhibited significant heterogeneity (I^2^>90%). We further queried heterogeneity by conducting an influence analysis. Influence analysis yielded a range of 18 percent to 23 percent for perpetration of IPV among active duty servicemembers.

###### Severity Effects

We then grouped studies by severity of IPV because how physical IPV was defined (e.g., at least moderate vs. any physical IPV) likely was a source of heterogeneity in the overall estimate of prevalence. For severity, we categorized violence using the same classification presented in the original studies when possible. The category of any physical violence could include a variety of physical abuse ranging from restraining and grabbing to sexual assault. Moderate physical violence included acts like shoving, kicking, and hitting with a fist. Severe physical violence included such acts as being “beaten up,” choking, or threatening to use (or using) a knife or gun.

Prevalence estimates varied by IPV severity with the broadest definition of IPV (any physical violence) yielding the highest estimates (25%), and the more restrictive definition yielding much lower point estimates (14% to 18%) (Figure 5). For the one IPV subgroup with more than one study (any physical violence), heterogeneity remained high (I^2^>90%).

Figure 5 Prevalence of physical IPV perpetration among active duty servicemembers by severity

###### Gender Effects

To test the effect of gender on 12-month prevalence estimates for IPV perpetration, we conducted a subgroup analysis (Figure 6). Five studies provided separate prevalence estimates by gender of the perpetrator,12,42,43,46-48,59 and two studies were conducted in gender-specific populations.45,56 Among women (n=11,923 in 7 studies), the point prevalence of IPV perpetration was 29 percent (95% CI, 18% to 39%) with significant heterogeneity (I^2^=99%). For men (n=69,024 in 7 studies), the point prevalence of IPV perpetration was 18 percent (95% CI, 15% to 21%) with significant heterogeneity (I^2^=99%).

Figure 6 Prevalence of physical IPV perpetration among active duty servicemembers by gender

###### Race Effects

There were insufficient studies to conduct subgroup analysis by race. Only two studies12,48 provided 12-month prevalence estimates for IPV perpetration by race or ethnicity in broad populations. Across these two studies, perpetration estimates did not appear to vary by race; prevalence ranged from seven percent (black populations) to nine percent (white populations).

##### IPV Victimization

We identified four studies that met criteria for a random-effects meta-analysis assessing physical IPV victimization among active duty servicemembers (n=47,303).47,48,54,59 Figure 7 shows the forest plot of the 12-month weighted estimated mean prevalence rate of physical IPV victimization. Pooled estimates across studies yielded a point estimate of 30% percent (95% CI, 17% to 43%); this estimate had significant heterogeneity (I^2^=100%).

Figure 7 Prevalence of physical IPV victimization among active duty servicemembers by era of service

To assess if prevalence rates varied by era of service, we conducted moderator analysis by date of recruitment. The weighted estimated mean prevalence rate of IPV victimization was 34 percent (n=4,559 from 3 studies; 95% CI, 20% to 48%) for servicemembers enrolled before 2001 and 19 percent (n=42,744 from 1 study; 95% CI, 19% to 20%) for those enrolled from 2001 to present. Both subgroups exhibited significant heterogeneity (I^2^>90%). We further queried heterogeneity by conducting an influence analysis. Influence analysis yielded a range of 25 percent to 33 percent for IPV victimization of active duty servicemembers.

###### Severity Effects

We grouped studies by severity of IPV because how IPV was defined was a likely source of heterogeneity in prevalence estimates. Prevalence estimates of IPV victimization varied by IPV severity with the most inclusive definition of IPV (any physical violence) yielding the highest estimates (33%), and the more restrictive definition yielding much lower point estimates (Figure 8). For the one IPV subgroup with more than one study (any physical violence), heterogeneity remained high (I^2^>90%)

Figure 8 Prevalence of physical IPV victimization among active duty servicemembers by severity

###### Gender Effects

To test the effect of gender on prevalence of IPV victimization, we conducted a subgroup analysis. Five studies provided separate prevalence estimates by gender,45,47,48,54,59 and one study was conducted in an all-female population56 (Figure 9). Among women, the point prevalence of IPV victimization was 26 percent (n=13,278 in 6 studies; 95% CI, 18% to 33%) with significant heterogeneity (I^2^=99%). For men, the point prevalence of IPV victimization was 31 percent (n=37,045 in 4 studies; 95% CI, 18% to 45%) and had significant heterogeneity (I^2^=99%).

Figure 9 Prevalence of physical IPV victimization among active duty servicemembers by gender

###### Race Effects

There were insufficient studies to conduct subgroup analysis by race. Only one study48 provided 12-month prevalence estimates for IPV perpetration by race or ethnicity in broad populations. In this study, IPV victimization estimates did not appear to vary by race; prevalence ranged from 10 percent (black and white populations) to 11 percent (Hispanic populations).

##### Summary of Prevalence of IPV Among Active Duty Servicemembers

Among active duty servicemembers, the prevalence of 12-month perpetration of physical abuse was 22 percent, and the prevalence of 12-month victimization of physical abuse was 30 percent (Table 5). Both estimates had high heterogeneity. Moderator analysis by era of service and gender all showed subgroup differences, but each pooled subgroup estimate also had high heterogeneity. There were insufficient studies to query subgroup differences by race and ethnicity. High heterogeneity can be partially explained by the inclusion of few studies in the pooled analysis (as described in “Expanded Guidance on Selected Quantitative Synthesis Topics” of the “Methods Guide”37). However, variability in prevalence is likely due to a combination of factors, including the small number of pooled studies.

Table 5 Prevalence of IPV among active duty servicemembers

Overall | | Era of Service | | Gender
| | Pre-2001 | Post-2001 | Female | Male
Perpetration | 22% | 26% | 14% | 29% | 18%
Victimization | 30% | 34% | 19% | 26% | 31%

#### Prevalence of IPV Among Veterans

We identified 12 studies that assessed IPV prevalence among Veteran populations.7,27,60,61,63-70 Of these, five assessed perpetration7,27,61,69,70 and eight assessed victimization.60,63-68,70 Below we report the results for perpetration and victimization separately.

##### IPV Perpetration

Of the five studies,7,27,61,69,70 prevalence of IPV perpetration among Veterans ranged from 15 to 60 percent. However, populations and outcomes were too heterogeneous to conduct a meta-analysis; thus we synthetized results qualitatively.

One fair-quality study61 focused on IPV between 184 heterosexual couples seeking therapy for relationship issues at an outpatient VA family therapy clinic. In all couples, the Veterans were male; 88 percent of the sample was white. Veterans had a primary diagnosis of PTSD (32%), depression (42%), or adjustment disorder (26%). The Veteran and partner separately completed the Conflict Tactic Scale (CTS) to assess perpetration of verbal or physical aggression towards an intimate partner in the past year. Overall prevalence of IPV perpetration by male Veterans was 30%. Additionally, couples data were used to create three violence profiles based on Veteran and female partners' self-reporting of IPV: (1) nonviolent couples (44%), (2) mutually violent couples (26%), and (3) one-sided violent couples (30%). Male Veterans with PTSD were significantly more likely to be in mutually violent couples than male Veterans in one-sided violence or nonviolent couples (p=0.007).

A fair-quality study70 assessed IPV perpetration among 89 female Vietnam Veterans and their male partners who completed the family interview component of the National Vietnam Veterans Readjustment Study.72 Most of the women Veterans were white (96%), and only 6 percent met diagnostic criteria of PTSD. The 8-item physical assault subscale was used to assess IPV prevalence. The CTS was administered to the male partners only; thus, this study only reports on female-perpetrated IPV as reported by male partners. According to reports from male partners, 22 percent of the female Veterans perpetrated physical IPV against their partners in the last year.

In another fair-quality study,69 236 combat-exposed male Veterans screened at a PTSD clinic for possible evaluation and treatment were queried for IPV perpetration using the 12-item physical assault subscale of the revised CTS (CTS2). Most of the men were white (76%) and served in the Vietnam War era (63%). Of the 161 partnered Veterans, 33 percent reported engaging in physical aggression toward their partner in the previous year.

A poor-quality study7 assessed IPV perpetration among 199 recently returning Afghanistan and Iraq Veterans referred for behavioral health evaluations. Most of the sample was male (89%), and most were white (53%). Based on nonmutually exclusive diagnosis codes, 72 percent had depression, 47 percent had PTSD, 35 percent had risky alcohol use, 46 percent had generalized anxiety disorder, and 12 percent had mania. This study assessed IPV using a study-developed tool to assess family readjustment and domestic abuse in the prior 6 months with the partnered, separated, or divorced Veterans (n=134). The measurement of domestic abuse included both low-intensity behaviors (e.g., psychological intimidation) and more severe physical violence. Overall, 60 percent of partnered, separated, or divorced Afghanistan and Iraq Veterans reported some domestic abuse in the last 6 months; however, this estimate included both physical IPV (e.g., shoving, pushing) and psychological aggression (e.g., shouting).

Another poor-quality study27 reported on verbal and physical IPV among World War II prisoners of war (n=331). The mean age of the sample was 80 years, and over half (57%) reported some depressive symptoms. The CTS was used to assess verbal and physical aggression. Overall, 15 percent reported physical IPV perpetration in the last year.

##### IPV Victimization

We identified eight studies that assessed victimization among Veterans.60,63-68,70 Of these, three65-67 were too heterogeneous to be combined in a summary estimate of IPV victimization due to differences in populations or outcomes. One study65 recruited from general mental health and specialty PTSD clinics. One reported on marital sexual violence,66 and another67 reported on rape committed by an intimate partner during service. These three studies were excluded from summary estimates. One study70 estimated prevalence of IPV in the last 12 months and could not be combined with the most common metric of IPV reported in other studies (i.e., lifetime IPV victimization). Results of this study are summarized qualitatively.

Four studies, comprising women-only samples, met criteria for a random-effects meta-analysis (n=2453) of exposure to lifetime IPV victimization.60,63,64,68 Figure 10 shows the forest plot of the lifetime weighted estimated mean prevalence of physical IPV victimization among Veterans. Pooled estimates across studies yielded a point estimate of 35 percent (95% CI, 25% to 47%) and had significant heterogeneity (I^2^=97%). No studies reported separate estimates by race or era of service.

Figure 10 Prevalence of lifetime physical IPV victimization among women Veterans

Two studies68,70 also reported on the on the prevalence of IPV victimization in the last year. Both studies were conducted among all-female populations. In one fair-quality study,68 406 women Veterans seeking primary care at a VA medical center were assessed for domestic violence using the Abuse Assessment Screen. Most of these women were white (57%), and only 19 percent had obtained any education beyond high school. Of these women Veterans, 7 percent reported being abused by a partner in the last year. In another fair-quality study described above,70 male partners of 89 female Vietnam Veterans were administered the CTS. According to self-reports from male partners, 12 percent of the female Veterans experienced physical IPV by their partners in the last year.

##### Summary of Prevalence of IPV Among Veterans

The prevalence of IPV perpetration within the last year ranged considerably (15% to 60%) across the five studies. However, most samples consisted of specialized clinical populations with a high mental health burden, and IPV perpetration was defined inconsistently across studies, ranging from physical abuse as measured on the CTS to any form of domestic abuse. Of the eight victimization studies, two reported on sexual violence only and none provided estimates for male Veterans. Four studies provided data amenable to meta-analysis. The pooled lifetime weighted estimated prevalence rate of physical IPV victimization among female Veterans yielded a point estimate of 35 percent (95% CI, 25% to 47%). The overall prevalence estimate had high heterogeneity, but limited data precluded moderation analysis to query for subgroup differences. Two studies reported on also reported on the on the prevalence of IPV victimization in the last year among women Veterans. Prevalence estimates in these two studies ranged from 7 percent to 12 percent.

## KEY QUESTION 2 For persons who are at risk for, experience, or commit intimate partner violence, what interventions are associated with decreased exposure to intimate partner violence and its associated physical harms, mental harms, or mortality?

Key Points
- We did not identify any SRs that evaluated primary prevention strategies for IPV.
- Most secondary interventions focused on reducing victimization. Only one SR focused on perpetration and synthesized the evidence for the use of cognitive behavioral therapy (CBT) with male perpetrators of IPV; this study identified one weakly favorable study and otherwise had inconclusive results.
- Standardized IPV screening interventions in health care settings increased the identification of victims of IPV when compared with nonstandard or nonuniversal screening. Screening interventions may decrease recurrence of IPV, though the effect is not sustained over time.
- Multicomponent screening interventions that included institutional support, effective screening protocols, initial and ongoing training of providers, and immediate access to referral services increased rates of IPV screening, disclosure, and identification. Using multicomponent screening interventions also has the potential to increase provider self-efficacy to perform IPV screening.
- Other interventions (counseling and advocacy) showed decreases in IPV victimization; however, the evidence is weak and often inconsistent.
- Secondary intervention research is largely inconclusive and faces many limitations, for several reasons, including high heterogeneity of samples, attrition, short followup periods, weak intervention effects, and small sample sizes.

### Description of Included Studies

We identified four good-quality2,73-75 and two fair-quality76,77 SRs that evaluated interventions aimed at decreasing exposure to IPV and its associated harms. No primary prevention interventions were identified. All six SRs evaluated studies that were secondary or tertiary interventions focused on populations with prior exposure to IPV. Four SRs compared screening interventions with usual care. Two SRs compared behavioral interventions for female victims with usual care or control groups; one SR examined CBT for male perpetrators of IPV against their female partners. One SR assessed brief, intensive advocacy interventions for female victims versus usual care or control condition. Characteristics of the six SRs are summarized in Table 6. Detailed quality assessments are presented in Appendix C.

Table 6 Study characteristics of the IPV systematic reviews

Study | Ramsay, 2009^74^ | O'Reilly, 2010^77^ | O'Campo, 2011^76^ | Smedslund, 2011^75^ | Choo, 2012^73^ | Nelson, 2012^2^
Quality | Good | Fair | Fair | Good | Good | Good
Population | Women ≥15 years of age who have experienced IPV | Pregnant women | Patients presenting to a health care setting | Men who are physically violent toward their female wife, partner, or ex-partner | Patients presenting to emergency departments | Women in health care settings without problems directly related to abuse, such as physical injuries
Intervention and Comparator | Intervention: Brief (>12h) or intensive (≤12h) advocacy interventions including safety planning [underlined: or] facilitation of access to refuges or shelters, emergency housing, [underlined: or] psychological care Comparator: Usual care or minimal additions such as IPV resource card or pamphlet | Intervention: (1) IPV screening for pregnant women (2) Counseling interventions for pregnant women who had experienced domestic violence Comparator: Heterogeneous group of comparison conditions (historical controls, usual care, screening with a different tool) | Intervention: IPV screening Comparator: Studies with no control, pre/post intervention control, and a defined control group | Intervention: Cognitive behavioral therapy, or recognizable elements thereof, delivered individually, couple/conjoint, or as group-based therapy Comparator: Studies were included with no treatment control and with other types of treatment as control | Intervention: Computer-based technologies for behavioral screening, interventions, or referrals Comparator: Heterogeneous group of comparison conditions (usual care, non-computer based IPV screen, computerized screen without IPV screening questions) | Intervention: (1) IPV screening (2) Heterogeneous counseling interventions for women positively detected by IPV screening Comparator: (1) Control group (2) Usual care
Setting | Various settings including health care or criminal justice facilities, domestic violence agencies, shelters or refuges, and community locations in the US (n=9) and Hong Kong (n=1) | Prenatal health clinics and hospitals in the US (n=7), Hong Kong (n=1), and Japan (n=1) | Health care settings in the US (n=10), Canada (n=2), United Kingdom (n=1), Australia (n=2), and New Zealand (n=2) | Various settings including prisons, individuals' homes, and community settings in the US (n=6) | Emergency departments in the US (n=4) and Canada (n=1) | [underlined: Screening study] Health care settings in the US (n=11), Canada (n=2), Brazil (n=1) and the United Kingdom (n=1) [underlined: Intervention study] Health care settings and home visits in the US (n=7) and Australia (n=1) [underlined: Harms study] Various settings including health care and community settings in the US (n=4), Canada (n=1), the United Kingdom (n=1), Australia (n=1), and not reported (n=7)^a^
Databases Searched | ASSIA British Nursing Index (CRCT and DARE) CINAHL EMBASE (Elsevier) Health Management Information Consortium IBBS MEDLINE metaRegister of Controlled Trials Midwives Information and Resource Index National Research Register PsycINFO SSCI | Cochrane Library EMBASE (Elsevier) MEDLINE PsycINFO | ASSIA EBM Reviews MEDLINE PsycINFO Social Sciences Abstracts SSCI Social Services Abstracts Sociological abstracts Violence and Abuse Abstracts Manual searches | Bibliography of Nordic Criminology CINAHL Cochrane Library (CRCT) Criminal Justice Abstracts EMBASE (Elsevier) ERIC Medline PsycINFO SIGLE Social Care Online Sociological Abstracts | Academic Search Premier CINAHL Cochrane Library (CRCT, DARE CDSR) EMBASE (Elsevier) Grey Literature Report Health Technology Assessments Database Nursing at OVID ProQuest PsycINFO PubMed SocINDEX | Cochrane Library (CRCT, CDSR) MEDLINE PsycINFO Scopus
Search Date | Only 2008 reported | November 2009 | No search date reported; SR included articles up to July 2010 | January 2010 | February 2011 | January 2012
Language Limits | None | English | English | None | English, Spanish, or French | English
Study Designs (n) | Patient-level or cluster RCT (n=5) Quasi-randomized controlled trial (n=5) | Comparative studies using any methodology Patient-level or cluster RCT (n=4) Historical control study (n=3) Case-control study (n=2) | RCT (n=0), case-control (n=0),case series (n=0), cohort (n=0), interrupted time series (n-0) Qualitative plus retrospective pre/post chart audit (n=2) Pre/post chart audit (n=1) Retrospective pre/post chart audit (n=1) Pre/post (n=2) Cross-sectional chart audit (n=2) Multicomponent evaluation (n=2) Multicomponent evaluation with pre/post (n=1) Multicomponent evaluation with nonrandomized controlled trial (n=3) Nonrandomized controlled trial (n=1) | RCT (n=6) | All observational and experimental studies Cross-sectional (n=1) Prospective cohort (n=1) Quasi-experimental (n=2) RCT (n=2) | RCT (n=35)
Range of Sample Sizes | 36 to 329 | 246 to 1440 | 16 to 46,929 | 64 to 861 | 87 to 7681 | 20 to 6743
Analytic Approach | Meta-analysis Qualitative summary | Meta-analysis Qualitative summary | Qualitative summary | Meta-analysis Qualitative summary | Qualitative summary | Qualitative summary
Primary Outcomes of Interest | Treatment/services received for IPV Rates of IPV victimization | IPV identification Rates of IPV Victimization Referral for treatment/services related to IPV | IPV identification Rates of IPV victimization | Change in IPV perpetration rates | IPV identification | Rates of IPV victimization
Secondary Outcomes of Interest | IPV-associated physical and mental harms | IPV-associated physical and mental harms | None | None | None | None
Source of Funding | Socialforsksnings Institut Nordic Campbell Centre, Denmark (private) | None | Ontario Ministry of Health and Long-Term Care (government) | Norwegian Knowledge Centre for the Health Services, Norway (government) Nordic Campbell Centre, Denmark (private) | Not reported | AHRQ

a Two U.S.-based studies were used for both screening and harms studies.

Abbreviations: AHRQ=Agency for Healthcare Research and Quality; ASSIA=Applied Social Sciences Index and Abstracts; CINAHL=Cumulative Index to Nursing and Allied Health Literature; CRCT=Central Registry of Controlled Trials (Cochrane); DARE=Database of Abstracts of Reviews of Effects; EBM=Evidence-Based Medicine; ERIC=Education Resources Information Center; IBBS=International Bibliography of the Social Sciences; IPV=intimate partner violence; SIGLE=System for Information on Grey Literature in Europe; SSCI=Social Sciences Citation Index.

All literature strategies included MEDLINE (via PubMed) and PsycINFO, and all but one SR included some aspect of the Cochrane Library. Additional sources of information were peer-reviewed literature databases (6), meeting abstracts and conference papers (2), clinical trial registries (2), unpublished theses and dissertations (2), grey literature reports (1) and manual searches of primary articles and reviews (2). Language limits were placed in four of the six SRs.

Two of the six SRs2,75 limited their primary studies to RCTs only; one SR74 included RCTs as well as studies with quasi-random allocation; and three studies73,76,77 assessed both experimental and observational studies. Five SRs used the qualitative approaches of narrative review2,73,75,77 and realist review.74 Two SRs74,75 used meta-analysis techniques with applicable data. All SRs except one77 completed quality assessments of included primary studies. Overall primary study quality was fair, with the most common quality problems unclear allocation concealment in RCTs and potential selection bias with quasi-experimental and observational studies.

All six SRs reported no conflicts of interest. Five SRs reported on funding sources. Of these, two were funded entirely by government agencies, one each in the United States and Canada. One was partially funded by a government agency in Norway with additional private funding. One study received private funding, and one study was unfunded.

Information on the populations studied was somewhat limited in all six SRs (Table 6). The number of primary articles included ranged from 6 to 35. Sample sizes varied widely and demographic data were reported sparely across the included SRs. No study reported whether active duty servicemembers (or their dependents) or Veterans were included in the sample. However, our review of the primary studies found that one study of CBT for perpetrators of IPV in the SR by Smedslund et al.,75 was conducted with Veterans at a Veterans Affairs Medical Center.

#### Qualitative Synthesis of IPV Intervention Strategies

We categorized the six SRs according to intervention strategy (e.g., screening, counseling). For each comparison, we focus our discussion on the SR having the highest quality and the most recent search date. We organize findings by outcomes of interest. The other SRs are described briefly when their findings differed importantly or they reported other relevant outcome analyses.

##### Screening Interventions

We identified four SRs that explored IPV screening interventions.2,73,76,77 Of these, the most recent and highest quality was the study by Nelson et al., 2012,^2^ with a search date of January 2012. This SR was commissioned by AHRQ to update the U.S. Preventive Services Task Force (USPSTF) recommendations for screening women for IPV. Overall, USPSTF recommends IPV screening for asymptomatic women of childbearing age and, further, that women who screen positive should be offered a referral for services.78 Below we focus on the findings of the SR by Nelson et al.2 that are relevant to outcomes of interest for this report.

###### Identification of IPV

Nelson et al.2 identified 12 fair- and 3 good-quality studies (15 total) that evaluated the diagnostic accuracy of 13 screening instruments in populations of asymptomatic women in a health care setting. Six instruments (i.e., HARK, HITS [English and Spanish versions] modified CTQ-SF, OVAT, StaT, and WAST) had sensitivity and specificity of greater than 80 percent for detecting women exposed to interpersonal violence (median number of items, 5; range, 4 to 28).2 This SR also reported adverse effects (e.g., feeling judged by provider, feeling uncomfortable being asked about IPV) that were identified in 3 RCTs, 11 descriptive studies, and 2 SRs. Findings indicated minimal adverse effects and low levels of harm (e.g., verbal abuse) related to IPV screening in women receiving health care services.

###### Treatment or Services Received for IPV

Nelson et al. identified 1 fair-quality cluster RCT with 6743 asymptomatic women who were randomly assigned to IPV screening or to usual care (i.e., no screening). Women were recruited at outpatient medical clinics in Canada and interviewed at baseline and 6, 12, and 18 months. Though 12-month prevalence of IPV differed a little at baseline between screened and nonscreened groups (13% vs. 12%), women who received screening were more likely to discuss IPV with their clinicians (44% vs. 8%). During the 18-month followup, screened and nonscreened women both had statistically similar increases in access to additional health care services.2

###### Changes in IPV-related Physical or Mental Harms

In the same fair-quality cluster RCT with 6743 asymptomatic women, screening versus usual care reduced IPV and improved health outcomes for both groups, but there was no statistically significant difference between groups. Women were recruited at outpatient medical clinics in Canada and interviewed at baseline and 6, 12, and 18 months. During the 18-month followup, screened and nonscreened women both had statistically similar decreases in IPV recurrence, PTSD symptoms, and alcohol problems. Further, both groups had improved scores for quality of life, depression, and mental health. These findings are limited because of the high loss to followup (43% screened, 41% unscreened) and significant differences between the individuals lost to followup and those included in all followups.

###### Other Findings Addressing Screening Interventions

The other three SRs73,76,77 were generally in agreement with the results of Nelson et al.2 Where differences occurred, they were largely due to different timing for outcomes, populations, and settings or differences in approach to data analysis. We summarize below the notable findings from the other three SRs:

- A good-quality SR with a February 2011 search date73 identified one good- and four moderate-quality studies of computerized IPV screening in emergency departments (sample size range, 87 to 7681), which reported on the use of computers to screen for IPV in emergency departments. This SR found high feasibility and acceptability of computerized screening in emergency departments, with few adverse effects reported and few negative consequences.
- One fair-quality realist review SR with a July 2010 search date76 identified 23 studies of 17 programs (sample size range, 16 to 46,929) that implemented IPV screening. Six of the 17 were deemed “comprehensive” interventions with multiple components of institutional support, use of effective screening protocols, thorough initial and ongoing training of providers, and immediate access to referral services. Multicomponent interventions successfully increased rates of IPV screening, disclosure, and identification and sustained these rates over time; the noncomprehensive sites (11 of 17) found no significant differences compared with control.
- Another fair-quality SR with a November 2009 search date77 identified five studies (sample size range, 246 to 1440) of screening women for domestic violence during pregnancy. Three of these studies used historical controls, one was a case control, and one was an RCT. Four studies were completed in the United States and one in Japan. Their qualitative analysis of the five screening studies found that the identification of domestic violence was significantly higher in standardized screening groups compared with a nonstandardized screening or no screening. There was also evidence that repeated screening during pregnancy increased identification rates.

#### Behavioral Interventions

We identified one good-quality SR75 that focused on male perpetrators of IPV and two SRs2,77 (one good quality, one fair) that synthesized evidence on behavioral interventions for female victims of IPV. Within the SRs, the group of behavioral strategies was heterogeneous (e.g., CBT, home visitations, general counseling). We summarize below the findings of the two good-quality SRs2,75 as they relate to the key outcomes of this report. We summarize the findings of the fair-quality SR77 when they add new information or contrast with those from the other two SRs.

##### Changes in IPV Perpetration

Smedslund et al.75 (January 2010 search date) examined six RCTs of CBT interventions for male perpetrators of physically violent behavior toward a female partner, wife, or ex-partner (sample size range, 64 to 861). Overall, the included studies were of low quality in this SR75 commissioned by the Cochrane Collaboration to assess whether CBT reduces violence in men who are physically violent toward their female partners. Four studies evaluated CBT versus a no-treatment control group, and two studies evaluated CBT versus other forms of treatment. Only one study (n=420) showed a statistically significant effect of CBT compared with no treatment on physical violence. A meta-analysis involving 1771 men showed a decrease in violence, but the estimate was not significant (relative risk 0.86; 95% CI, 0.54 to 1.38) and had high heterogeneity (I^2^=79%). For the two studies where CBT was compared with another form of treatment, the results were inconclusive. This SR rated the strength of evidence as insufficient for CBT as a treatment for IPV perpetrators.

##### Changes in IPV Victimization and IPV-related Physical or Mental Harms

The good-quality SR by Nelson et al.2 (January 2012 search date) assessed 6 RCTs (1 good quality, 4 fair, and 1 poor) of behavioral interventions for women who had screened positive for IPV in a health care setting. Overall 4169 women participated in these interventions (range, 174 to 1044). Three RCTs assessed interventions for pregnant and postpartum women, and three targeted women regardless of pregnancy status, all in health care settings. The intervention methods were heterogeneous and included paraprofessional postpartum home visitation versus usual care, nurse case management versus usual care, counseling intervention during or after pregnancy versus usual care, counseling intervention at a family planning clinic versus usual care, wallet-sized referral card versus 20-minute nurse management protocol, and trained mentor home visitation versus usual care.

An RCT of counseling versus usual care during pregnancy reported decreases in IPV events during pregnancy and postpartum period (adjusted odds ratio, 0.48; 95% CI, 0.29 to 0.80) and better birth outcomes (i.e., birth weight <1500 g, gestational age) in the counseling group. One of two RCTs of home visitation versus usual care for young mothers resulted in improved IPV outcomes with visitation. Another study of home visitation versus usual care showed a decrease in IPV victimization, but depression, physical well-being, mental well-being, and parental stress were not statistically significantly better in the home visitation group. Two RCTs showed improved outcomes in intervention and control groups with no statistically significant differences between groups (counseling vs. referral cards; nurse management vs. usual care in pregnancy). Another RCT of counseling versus usual care found decreased pregnancy coercion at followup (adjusted odds ratio 0.29; 95% CI, 0.09 to 0.91) and discontinuation of unsafe relationship when compared with usual care. Overall, these studies show a positive signal for a heterogeneous group of behavioral interventions; however, Nelson et al.2 found limited statistically significant evidence to support interventions. Findings should be interpreted with caution due to small sample sizes and high attrition across included studies.

##### Other Findings Addressing Behavioral Interventions

We identified one fair-quality SR77 that included four intervention studies (one case-control and three RCTs) with a total of 859 participants. Behavioral interventions included (1) prenatal and postnatal counseling using trained counselors, nurses, and midwives and (2) an enhanced intervention of counseling plus a trained peer mentor. Both interventions were compared with usual care or with receipt of a wallet-sized community resource card. The results for effectiveness of counseling were mixed, with significant within-group decreases in physical harm from baseline to followup in two of the four studies but no significant between-group differences within each study. The counseling intervention compared with the enhanced counseling plus mentoring intervention showed a significant decrease in threat of physical harm reported by the enhanced group compared with the counseling-only group at 2 months. The SR by O'Reilly et al.77 supports the findings of the good-quality SRs and also concludes that there is limited evidence for the effectiveness of identified interventions with the present quantity and quality of intervention studies available.

#### Advocacy Interventions

We identified one good-quality SR74 with a search date of July 2008 that evaluated 10 advocacy intervention studies having a total of 1527 participants. This SR, funded by Socialforsksnings Institut at the Nordic Campbell Centre in Denmark, had the objective of assessing effects of advocacy interventions conducted in diverse settings on women who have experienced abuse by an intimate partner. For the purpose of this SR, advocacy interventions were defined as interventions with the following core activities: education and support to enhance provision of legal, housing, and financial advice; facilitating access and use of community shelters and emergency housing and psychological interventions; and guidance on safety planning. This SR included a diverse group of interventions, categorized into brief (<12 hours duration) or intensive (≥12 hours duration), with heterogeneous outcome measures and durations of followup (ranging from immediate postintervention to 3 years). Settings included domestic violence shelters; emergency departments; in-home visits (recruited from shelter); general community settings (recruited from shelter); antenatal clinics; the family violence unit of a district attorney's office; general public health clinics; and Women, Infants, and Children clinics.

##### Treatment or Services Received for IPV

The use of services related to IPV exposure (e.g., use of counseling, protection orders, use of shelters) was measured only in two primary studies, both of which assessed brief advocacy interventions compared with controls. Neither study show statistically significant differences in use of services between the advocacy intervention and control participants. However, one study showed a positive trend in use or services related to advocacy interventions both in short-term and longer term followup assessments (12 months followup standard mean difference [SMD] 0.22; 95% CI, 0.00 to 0.44; and at 12-24 months followup SMD 0.15; 95% CI, -0.07 to 0.37).74

##### Changes in IPV Victimization and IPV-related Physical or Mental Harms

Six interventions identified physical abuse outcomes; of these, three evaluated brief advocacy interventions and three evaluated intensive interventions compared with usual care. Five of the six studies found no significant differences in rates of physical abuse between intervention and control groups. Three pooled studies of intensive advocacy intervention (n=295) found a significant reduction in physical abuse at 24 months but not at shorter or longer time periods (odds ratio 0.43; 95% CI, 0.23 to 0.80). The one good-quality intervention study (n=106) observed a reduction in minor physical abuse among pregnant women in the intervention group but no change in severe abuse. No significant effects were found at 12 months followup for level of sexual abuse (n=106) (change-score SMD -0.11; 95% CI, -0.49 to 0.26) or overall abuse (2 studies, total n=131).74 Across two pooled studies (n=232), brief interventions increased use of safety behaviors (e.g., use of coded telephone messages to a friend, keeping clothes at a friend's house, hiding emergency money) at 12 months (weighted mean difference [WMD] 0.60; 95% CI, 0.14 to 1.06) and at 12 to 24 months followup (WMD 0.48; 95% CI, 0.04 to 0.92).

No significant effects were found for depression (3 studies, n=308) (WMD -0.05; 95% CI, -0.19 to 0.09), anxiety/psychological distress (4 studies, n=231) (SMD -0.16; 95% CI, -0.39 to 0.06), or PTSD (n=53) (SMD -0.45, 95% CI -1.00 to 0.11). Overall, advocacy interventions show promise in reducing IPV victimization, but the effects on other physical and mental harms were inconclusive.74 Authors of this SR rated the strength of evidence for advocacy interventions as insufficient.

#### Summary of IPV Intervention Strategies

- Screening interventions improve identification of IPV victimization in women.
- Screening interventions may improve other physical and mental harms when paired with behavioral interventions for women who screen positive for IPV, but there is insufficient evidence to support this conclusion.
- Other secondary prevention interventions, including behavioral and advocacy, show a positive but weak signal for improving IPV victimization outcomes and related physical and mental harms; evidence is insufficient at this time.
- Available data are limited due to the small number of studies available, the heterogeneity of interventions and outcome measures, and the quality of the studies completed.