# REFERENCES

1 Black MC, Basile KC, Breiding MJ, Smith SG, Walters ML, Merrick MT, Chen J, Stevens MR. The National Intimate Partner and Sexual Violence Survey (NISVS):2010 Summary Report. Atlanta, GA. National Center for Injury Prevention and Control, Centers for Disease Control and Prevention. 2011.
2 Nelson HD, Bougatsos C, Blazina I. Screening women for intimate partner violence: a systematic review to update the U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2012;156(11):796-808. W-279, W-280, W-281, W-282. [pmid: 22565034].
3 Flynn A, Graham K. “Why did it happen?” A review and conceptual framework for research on perpetrators' and victims' explanations for intimate partner violence. Aggress Violent Behav. 2010;15(3):239-251. [pmid: 20436933].
4 Sarkar NN. The impact of intimate partner violence on women's reproductive health and pregnancy outcome. J Obstet Gynaecol. 2008;28(3):266-71. [pmid: 18569465].
5 Nathanson AM, Shorey RC, Tirone V, et al. The Prevalence of Mental Health Disorders in a Community Sample of Female Victims of Intimate Partner Violence. Partner Abuse. 2012;3(1):59-75. [pmid: 22741043].
6 Max W, Rice DP, Finkelstein E, et al. The economic toll of intimate partner violence against women in the United States. Violence Vict. 2004;19(3):259-72. [pmid: 15631280].
7 Sayers SL, Farrow VA, Ross J, et al. Family problems among recently returned military veterans referred for a mental health evaluation. J Clin Psychiatry. 2009;70(2):163-70. [pmid: 19210950].
8 Martin SL, Gibbs DA, Johnson RE, et al. Substance use by soldiers who abuse their spouses. Violence Against Women. 2010;16(11):1295-310. [pmid: 21097964].
9 Taft CT, Kachadourian LK, Suvak MK, et al. Examining impelling and disinhibiting factors for intimate partner violence in veterans. J Fam Psychol. 2012;26(2):285-9. [pmid: 22369461].
10 Marshall AD, Panuzio J, Taft CT. Intimate partner violence among military veterans and active duty servicemen. Clin Psychol Rev. 2005;25(7):862-76. [pmid: 16006025].
11 Teten AL, Schumacher JA, Bailey SD, et al. Male-to-female sexual aggression among Iraq, Afghanistan, and Vietnam veterans: co-occurring substance abuse and intimate partner aggression. J Trauma Stress. 2009;22(4):307-11. [pmid: 19588515].
12 Fonseca CA, Schmaling KB, Stoever C, et al. Variables associated with intimate partner violence in a deploying military sample. Mil Med. 2006;171(7):627-31. [pmid: 16895129].
13 Campbell JC, Garza MA, Gielen AC, et al. Intimate Partner Violence and Abuse among Active Duty Military Women. Violence Against Women. 2003;9(9):1072-1092.
14 McCarroll JE, Thayer LE, Liu X, et al. Spouse abuse recidivism in the U.S. Army by gender and military status. J Consult Clin Psychol. 2000;68(3):521-5. [pmid: 10883570].
15 McCarroll JE, Ursano RJ, Liu X, et al. Deployment and the probability of spousal aggression by U.S. Army soldiers. Mil Med. 2000;165(1):41-4. [pmid: 10658427].
16 Teten AL, Schumacher JA, Taft CT, et al. Intimate partner aggression perpetrated and sustained by male Afghanistan, Iraq, and Vietnam veterans with and without posttraumatic stress disorder. J Interpers Violence. 2010;25(9):1612-30. [pmid: 20023200].
17 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol. 2009;62(10):1006-12. [pmid: 19631508].
18 Bohannon JR, Dosser DA Jr, Lindley SE. Using couple data to determine domestic violence rates: an attempt to replicate previous work. Violence Vict. 1995;10(2):133-41. [pmid: 8599598].
19 Bradley KA, Bush KR, Davis TM, et al. Binge drinking among female Veterans Affairs patients: prevalence and associated risks. Psychol Addict Behav. 2001;15(4):297-305. [pmid: 11767260].
20 Byrne CA, Riggs DS. The cycle of trauma; relationship aggression in male Vietnam veterans with symptoms of posttraumatic stress disorder. Violence Vict. 1996;11(3):213-25. [pmid: 9125790].
21 Cook JM, Riggs DS, Thompson R, et al. Posttraumatic stress disorder and current relationship functioning among World War II ex-prisoners of war. J Fam Psychol. 2004;18(1):36-45. [pmid: 14992608].
22 Crouthamel J. Male sexuality and psychological trauma: soldiers and sexual disorder in World War I and Weimar Germany. J Hist Sex. 2008;17(1):60-84. [pmid: 19260157].
23 Gondolf RAF EW. Wife assault among VA alcohol rehabilitation patients. Hosp Community Psychiatry. 1991;42:74-79. [pmid: 2026410].
24 Hiley-Young B, Blake DD, Abueg FR, et al. Warzone violence in Vietnam: an examination of premilitary, military, and postmilitary factors in PTSD in-patients. J Trauma Stress. 1995;8(1):125-41. [pmid: 7712051].
25 Jordan BK, Marmar CR, Fairbank JA, et al. Problems in families of male Vietnam veterans with posttraumatic stress disorder. J Consult Clin Psychol. 1992;60(6):916-26. [pmid: 1460153].
26 Petrick N, Rosenberg AM, Watson CG. Combat experience and youth: Influences on reported violence against women. Prof Psychol Res Pr. 1983;14:895-9.
27 O'Donnell C, Cook JM, Thompson R, et al. Verbal and physical aggression in World War II former prisoners of war: role of posttraumatic stress disorder and depression. J Trauma Stress. 2006;19(6):859-66. [pmid: 17195970].
28 Pan HS, Neidig PH, O'Leary KD. Predicting mild and severe husband-to-wife physical aggression. J Consult Clin Psychol. 1994;62(5):975-81. [pmid: 7806729].
29 Preece J. The lives of the RAF revisited: The biographical turn. Memory Studies. 2010;3(2):151-163.
30 Schnurr PP, Friedman MJ, Engel CC, et al. Issues in the design of multisite clinical trials of psychotherapy: VA Cooperative Study No. 494 as an example. Contemp Clin Trials. 2005;26(6):626-636. [pmid: 16236558].
31 Sharps PW. Abuse and prenatal outcomes in military women. TriService Nursing Research Program (TSNRP). 2008. pages unknown p.
32 American College of Obstetricians and Gynecologists (ACOG). Domestic violence and Army deployment. ACOG Clinical Review. 2006;11(2):12-12.
33 Hoy D, Brooks P, Woolf A, et al. Assessing risk of bias in prevalence studies: modification of an existing tool and evidence of interrater agreement. J Clin Epidemiol. 2012;65(9):934-9. [pmid: 22742910].
34 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
35 Borenstein M, Hedges L, Higgins JA, et al. Comprehensive Meta-analysis Version 2. Biostat. Englewood, NJ. 2005.
36 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
37 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(12)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012. www.effectivehealthcare.ahrq.gov.
38 Schunemann HJ, Oxman AD, Brozek J, et al. Grading quality of evidence and strength of recommendations for diagnostic tests and strategies. BMJ. 2008;336(7653):1106-10. [pmid: 18483053].
39 Lutgendorf MA, Thagard A, Rockswold PD, et al. Domestic violence screening of obstetric triage patients in a military population. J Perinatol. 2012.
40 Slep AM, Foran HM, Heyman RE, et al. Unique risk and protective factors for partner aggression in a large scale air force survey. J Community Health. 2010;35(4):375-83. [pmid: 20373136].
41 Lutgendorf MA, Busch JM, Doherty DA, et al. Prevalence of domestic violence in a pregnant military population. Obstet Gynecol. 2009;113(4):866-72. [pmid: 19305332].
42 Merrill LL, Crouch JL, Thomsen CJ, et al. Perpetration of severe intimate partner violence: premilitary and second year of service rates. Mil Med. 2005;170(8):705-9. [pmid: 16173214].
43 Newby JH, Ursano RJ, McCarroll JE, et al. Postdeployment domestic violence by U.S. Army soldiers. Mil Med. 2005;170(8):643-7. [pmid: 16173201].
44 McCarroll JE, Ursano RJ, Newby JH, et al. Domestic violence and deployment in US Army soldiers. J Nerv Ment Dis. 2003;191(1):3-9. [pmid: 12544593].
45 Heyman RE, Neidig PH. A comparison of spousal aggression prevalence rates in U.S. Army and civilian representative samples. J Nerv Ment Dis. 1999;67(2):239-42.
46 Rosen LN, Knudson KH, Fancher P. Intimate partner violence among U.S. Army soldiers in Alaska: a comparison of reported rates and survey results. Mil Med. 2002;167(11):ii-iii. [pmid: 12448608].
47 Rosen LN, Parmley AM, Knudson KH, et al. Gender differences in the experience of intimate partner violence among active duty U.S. Army soldiers. Mil Med. 2002;167(12):959-63. [pmid: 12502167].
48 Foran HM, Slep AM, Heyman RE, et al. Prevalences of intimate partner violence in a representative U.S. Air Force sample. J Consult Clin Psychol. 2011;79(3):391-7. [pmid: 21480693].
49 Rosen LN, Parmley AM, Knudson KH, et al. Intimate partner violence among married male U.S. Army soldiers: ethnicity as a factor in self-reported perpetration and victimization. Violence Vict. 2002;17(5):607-22. [pmid: 12477101].
50 Forgey MA, Badger L. Patterns of intimate partner violence and associated risk factors among married enlisted female soldiers. Violence Vict. 2010;25(1):45-61. [pmid: 20229693].
51 Rosen LN, Kaminski RJ, Parmley AM, et al. The effects of peer group climate on intimate partner violence among married male U.S. Army soldiers. Violence Against Women. 2003;9(9):1045-1071.
52 Schmaling KB, Blume AW, Russell ML. Intimate Partner Violence and Relationship Dissolution Among Reserve Soldiers. Mil Psychol. 2011;23(6):685-699.
53 Stander VA, Thomsen CJ, Merrill LL, et al. Gender and Military Contextual Risk Factors for Intimate Partner Aggression. Mil Psychol. 2011;23(6):639-658.
54 Crouch JL, Thomsen CJ, Milner JS, et al. Heterosexual intimate partner violence among Navy personnel: gender differences in incidence and consequences. Mil Psychol. 2009;21:S1-s15.
55 O'Campo P, Kub J, Woods A, et al. Depression, PTSD, and Comorbidity Related to Intimate Partner Violence in Civilian and Military Women. Brief Treatment and Crisis Intervention. 2006;6(2):99-110.
56 Forgey M, Badger L. Patterns of Intimate Partner Violence Among Married Women in the Military: Type, Level, Directionality and Consequences. J Fam Violence. 2006;21(6):369-380.
57 Newby JH, Ursano RJ, McCarroll JE, et al. Spousal aggression by U.S. Army female soldiers toward employed and unemployed civilian husbands. Am J Orthopsychiatry. 2003;73(3):288-93. [pmid: 12921209].
58 McCarroll JE, Ursano RJ, Liu X, et al. Deployment and the Probability of Spousal Aggression by US Army Soldiers. Mil Med. 2010;175(5):352-356. [pmid: 20486508].
59 Merrill LL, Hervig LK, Milner JS, et al. Premilitary intimate partner conflict resolution in a navy basic trainee sample. Mil Psychol. 1998;10(1):1-15.
60 Dichter ME, Cerulli C, Bossarte RM. Intimate partner violence victimization among women veterans and associated heart health risks. Womens Health Issues. 2011;21(4 Suppl):S190-4. [pmid: 21724140].
61 Teten AL, Sherman MD, Han X. Violence between therapy-seeking veterans and their partners: prevalence and characteristics of nonviolent, mutually violent, and one-sided violent couples. J Interpers Violence. 2009;24(1):111-27. [pmid: 18378807].
62 Sherman MD, Sautter F, Jackson MH, et al. Domestic violence in veterans with posttraumatic stress disorder who seek couples therapy. J Marital Fam Ther. 2006;32(4):479-90. [pmid: 17120520].
63 Dobie DJ, Kivlahan DR, Maynard C, et al. Posttraumatic stress disorder in female veterans: association with self-reported health problems and functional impairment. Arch Intern Med. 2004;164(4):394-400. [pmid: 14980990].
64 Coyle BS, Wolan DL, Van Horn AS. The prevalence of physical and sexual abuse in women veterans seeking care at a Veterans Affairs Medical Center. Mil Med. 1996;161(10):588-93. [pmid: 8918119].
65 Luterek JA, Bittinger JN, Simpson TL. Posttraumatic Sequelae Associated with Military Sexual Trauma in Female Veterans Enrolled in VA Outpatient Mental Health Clinics. J Trauma Dissociation. 2011;12(3):261-274. [pmid: 21534095].
66 Campbell R, Raja S. The sexual assault and secondary victimization of female veterans: Help-seeking experiences with military and civilian social systems. Psychol Women Q. 2005;29(1):97-106.
67 Sadler AG, Booth BM, Cook BL, et al. Factors associated with women's risk of rape in the military environment. Am J Ind Med. 2003;43(3):262-273. [pmid: 12594773].
68 Caralis PV, Musialowski R. Women's experiences with domestic violence and their attitudes and expectations regarding medical care of abuse victims. South Med J. 1997;90(11):1075-1080. [pmid: 9386045].
69 Taft CT, Weatherill RP, Woodward HE, et al. Intimate partner and general aggression perpetration among combat veterans presenting to a posttraumatic stress disorder clinic. Am J Orthopsychiatry. 2009;79(4):461-8. [pmid: 20099937].
70 Dutra L, de Blank G, Scheiderer E, et al. Correlates of Female Veterans' Perpetration of Relationship Aggression. Psychol Trauma. 2012;4(3):323-329.
71 Campbell R, Greeson MR, Bybee D, et al. The co-occurrence of childhood sexual abuse, adult sexual assault, intimate partner violence, and sexual harassment: a mediational model of posttraumatic stress disorder and physical health outcomes. J Consult Clin Psychol. 2008;76(2):194-207. [pmid: 18377117].
72 Kulka RA, Schlenger WE, Fairbank JA, et al. Trauma and the Vietnam War generation: Report of findings from the National Vietnam Veterans Readjustment Study. New York. Brunner/Mazel. 1990.
73 Choo EK, Ranney ML, Aggarwal N, et al. A systematic review of emergency department technology-based behavioral health interventions. Acad Emerg Med. 2012;19(3):318-28. [pmid: 22435865].
74 Ramsay J, Carter Y, Davidson L, et al. Advocacy interventions to reduce or eliminate violence and promote the physical and psychosocial well-being of women who experience intimate partner abuse. Cochrane Database Syst Rev. 2009;3:CD005043. [pmid: 19588364].
75 Smedslund G, Dalsbo TK, Steiro AK, et al. Cognitive behavioural therapy for men who physically abuse their female partner. Cochrane Database of Systematic Reviews 2011, Issue 2. Art. No.: CD006048. Cochrane Database Syst Rev. 2011;3:CD006048. [pmid: 17636823].
76 O'Campo P, Kirst M, Tsamis C, et al. Implementing successful intimate partner violence screening programs in health care settings: evidence generated from a realist-informed systematic review. Soc Sci Med. 2011;72(6):855-66. [pmid: 21330026].
77 O'Reilly R, Beale B, Gillies D. Screening and intervention for domestic violence during pregnancy care: a systematic review. Trauma Violence Abuse. 2010;11(4):190-201. [pmid: 20688785].
78 Moyer VA. Screening for intimate partner violence and abuse of elderly and vulnerable adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013;158(6):478-86. [pmid: 23338828].
79 Bair-Merritt MH, Crowne SS, Thompson DA, et al. Why do women use intimate partner violence? A systematic review of women's motivations. Trauma Violence Abuse. 2010;11(4):178-89. [pmid: 20823071].
80 Institute of Medicine. Available at: http://www.iom.edu/. July 26, 2013.
81 Frayne SM, Phibbs CS, Friedman SA, et al. Sourcebook: Women Veterans in the Veterans Health Administration. Sociodemographics and Use of VHA and Non-VA Care (Fee). Women's Health Evaluation Initiative, Women's Health Services, Veterans Health Administration, Department of Veterans Affairs. Washington DC. October. 2012;2. Available at: http://www.womenshealth.va.gov/. July 26, 2013.
82 Sanford C, Marshall SW, Martin SL, et al. Deaths from violence in North Carolina, 2004: how deaths differ in females and males. Inj Pre. 2006;12(Suppl 2):ii10-ii16.
83 Bureau of Justice Statistics. Homicide Trends in the United States, 1980-2008. Available at: http://bjs.gov/index.cfm?ty=pbdetail&iid=2221. April 19, 2013.
84 Moracco KE, Runyan CW, Loomis DP, et al. Killed on the clock: a population-based study of workplace homicide, 1977-1991. Am J Ind Med. 2000;37(6):629-36. [pmid: 10797506].
85 American Congress of Obstetricians and Gynecologists. ACOG Committee Opinion No. 518: Intimate partner violence. Obstet Gynecol. 2012;119(2 Pt 1):412-7. [pmid: 22270317].
86 American Medical Association. Opinion H-515.965 Family and Intimate Partner Violence. Available at: http://www.ama-assn.org/ama1/pub/upload/mm/PolicyFinder/policyfiles/HnE/H-515.965.HTM. April 19, 2013.
87 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.). AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=735&pageaction=displayproduct. April 8, 2012.
88 Myers E, McBroom AJ, Shen L, et al. Value-of-Information Analysis for Patient-Centered Outcomes Research Prioritization. Report prepared by the Duke Evidence-based Practice Center. Patient-Centered Outcomes Research Institute. March. 2012.