# METHODS

## TOPIC DEVELOPMENT

This review was commissioned by the VA's Evidence-based Synthesis Program. The topic was nominated after a topic refinement process that included a preliminary review of published peer-reviewed literature, consultation with internal partners and investigators, and consultation with key stakeholders. We further developed and refined the key questions (KQs) based on a preliminary review of published peer-reviewed literature in consultation with VA and non-VA experts.

The final KQs were:

KQ 1. What is the prevalence of intimate partner violence among Veterans and active duty servicemembers, and does the prevalence vary by cohort (e.g., Vietnam era, OEF/OIF/OND era), gender, or race?

KQ 2. For persons who are at risk for, experience, or commit intimate partner violence, what interventions are associated with decreased exposure to intimate partner violence and its associated physical harms, mental harms, or mortality?

## ANALYTIC FRAMEWORK

We followed a standard protocol for all steps of this review; certain methods map to the PRISMA checklist.17 Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic framework for assessing intimate partner violence

Abbreviations: IPV=intimate partner violence; KQ=key question

## SEARCH STRATEGY

We used different literature search strategies for KQ 1 and KQ 2. Prevalence of IPV (KQ 1) was approached using primary research articles so that we could compare populations and trends over time. Treatment interventions (KQ 2) were approached through a synthesis of SRs because there were numerous potential intervention strategies and several current, high-quality SRs available on this topic. For prevalence, we searched MEDLINE^®^ (via PubMed^®^), CINAHL^®^, PsycINFO^®^, and Social Sciences Citation Index (a subset of Web of Science) from inception through December 2012 for peer-reviewed publications providing prevalence rates for IPV. However, through the peer review process we were alerted to one citation that was not identified in our original search strategy. Consequently, we broadened our search strategy such that it would identify this new citation. We then updated our PubMed, CINAHL, PsycINFO searches in June 2013. (We did not update the Social Sciences Citation Index in June 2013 because this database did not yield any relevant citations not identified in the other databases during the initial search.) For treatment intervention strategies, we searched PubMed, EMBASE^®^, CINAHL, PsycINFO, and the Cochrane Database of Systematic Reviews for peer-reviewed SRs from January 2007 through December 2012.

We developed our search strategy in consultation with an experienced search librarian. We used the National Library of Medicine's Medical Subject Headings (MeSH) keyword nomenclature and text words for populations of interest, types of intimate partner abuse (Spouse Abuse [Mesh], Domestic Violence[Mesh]), intervention strategies (screening, counseling, rehabilitation), and validated search terms for both prevalence statistics and SRs. We limited both searches to articles published in the English language involving human subjects 18 years of age and older. The KQ 1 search was limited to Veterans and military and active duty populations. The KQ 2 search was limited to SRs with search dates on or after January 1, 2007. The full search strategy is provided in Appendix A.

We supplemented the electronic searches with a manual search of citations from a set of key primary and review articles.2,13,18-32 The reference list for identified pivotal articles was hand-searched and cross-referenced against our library in order to retrieve additional articles. All citations were imported into two electronic databases (for referencing, EndNote^®^ Version X5, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## STUDY SELECTION

Using prespecified inclusion and exclusion criteria, two reviewers assessed titles and abstracts for relevance to the KQs. Full-text articles identified by either reviewer as potentially relevant were retrieved for further review and examined by two reviewers against the eligibility criteria. Disagreements on inclusion, exclusion, or the major reason for exclusion were resolved by discussion or by a third reviewer. The criteria to screen articles for inclusion or exclusion at both the title-and-abstract and full-text screening stages for KQ 1 and KQ 2 are detailed in Table 2. Appendix B contains bibliographic information for all included studies.

Table 2 Summary of inclusion and exclusion criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | KQ 1: U.S. Veterans and active duty servicemembers KQs 1 and 2: Adults (≥18 years of age) | KQs 1 and 2; - 18 years of age; - Incarcerated populations; :
Interventions | KQ 1: Not applicable KQ 2:; - Primary IPV prevention strategies (e.g., marital conflicts, communication, interaction-style counseling); - Secondary IPV prevention strategies focused on reducing rates of IPV among those who commit or experience IPV (e.g., screening, counseling to reduce perpetration or victimization, emergency shelters, training of health care or law enforcement personnel) | KQ 2: Changes to federal, state, or local laws
Comparators | KQ 1: Not applicable KQ 2: Usual care or other primary or secondary IPV prevention interventions | None
Outcomes | KQ 1:; - Proportion of U.S. military servicemembers or Veterans who have committed IPV; - Proportion of U.S. military servicemembers or Veterans who have experienced IPV; - Outcomes measured by self-report or interviewer-based assessment; KQ 2: Study must report at least one of the following:; - Change in IPV perpetration; - Rates of IPV victimization; - Identification of IPV; - Referral for services related to IPV; - Treatment or services received for IPV; - Change in attitudes toward IPV (for primary prevention only); KQ 2: Secondary outcomes of interest:; - IPV-associated physical harms (e.g., injuries, sexual assault) or mental harms (e.g., PTSD); - IPV-related mortality; - Markers of healthy relationship norms (e.g., satisfaction, communication, conflict-resolution skills); Outcomes measured by self-report or interviewer-based assessment, except referrals and treatment rates, which may be assessed by chart reviews | KQ 1: Assessment of any aspect of IPV based only on chart review or assessment of administrative data KQ 2: Reports only relationship outcomes (e.g., conflict-resolution skills), physical harms (e.g., gastrointestinal distress, chronic pain), or mental health harms (e.g., depression, PTSD) and does not provide outcome data on rates of IPV, intermediate IPV screening outcomes of interest, or attitudes toward IPV
Timing | KQ 1:; - Lifetime exposure to IPV; - IPV exposure that occurred during service in the military; - IPV exposure that occurred after discharge from the military; KQ 2: End of treatment or longer | KQ 2: No postintervention exposure assessments
Setting | KQ 1:; - Military settings (domestic or abroad); - Population or community settings; KQs 1 and 2:; - Outpatient general medical settings (e.g., internal medicine, family medicine, etc.); - VA health care settings for outpatient care; - Emergency medicine; - Outpatient mental health; - Mixed clinical settings (if of interest); - Community settings | KQs 1 and 2: Correctional facilities and hospital inpatient setting
Study designs | KQ 1:; - Original data; - Prospective and retrospective observational studies; - Cross-sectional studies; KQ 2: Systematic review (i.e., methods section has search strategy and data synthesis plan) | KQ 1:; - Not a research study (e.g., editorial, letter); - N ≤99; KQ 2: Not a systematic review (e.g., narrative review)
Publications | KQ 1:; - Peer-reviewed research articles^a^; - English-language^b^; - Full publications; KQ 2:; - English-language; - Peer-reviewed articles; - Full publications; - Relevant good- or fair-quality systematic review; - Published from January 1, 2007 forward^c^ | KQs 1 and 2:; - Abstract only; - Not English-language; KQ 2:; - Abstract only; - Not English-language; - Poor-quality systematic review; - Published prior to 2007

Abbreviations: KQ=key question; RCT=randomized controlled trial

a Peer-reviewed article is defined as a published article of original research that has been written by scientists or professionals in a field of study; has been evaluated for scientific quality and correctness by other experts in the same field who are outside of the publishing or sponsoring organization; and has been reviewed either by the author's identity being blinded or the reviewers' identity being blinded, or both.

b Given the high volume of English-language publications (including the majority of known important studies), we have excluded non-English-language articles because the resources required to translate non-English-language articles would not be justified by the low potential likelihood of identifying relevant data unavailable from English-language sources.

c We originally searched MEDLINE from January 1, 2002, to the present. Results of earlier reviews were captured in the findings of more recent reviews. Thus, we revised our search strategy to include systematic reviews only from January 1, 2007, forward.

## DATA ABSTRACTION

Before general use, the abstraction form templates, designed specifically for this report, were piloted on a sample of included articles and revised to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors. We gave particular attention to how IPV was defined in each study, the study setting, the measurements used to assess outcomes and mode of administration, and the characteristics of the patient (KQ 1) or study (KQ 2). Select data from published reports were then abstracted into the final abstraction form by one trained reviewer. All data abstractions were confirmed by a second reviewer. Disagreements were resolved by consensus or by obtaining a third reviewer's opinion when consensus could not be reached.

We abstracted the following key information for each included study, if reported:

- Study design
- Population characteristics
- Inclusion criteria
- Exclusion criteria
- Funding source
- Outcomes

Specifically for the prevalence studies for KQ 1, we abstracted:

- Enrollment (for prevalence data, including recruitment dates)
  ○ Assessed for eligibility
  ○ Number eligible
  ○ Completed survey or other primary strategy
  ○ Completed followup
- Study site, setting, and/or geographic location
- Assessment of IPV measurement
  ○ Name of IPV survey instrument
  ○ Mode of administration for IPV survey instrument
  ○ Types of abuse captured by IPV survey instrument
  ○ Description of person reporting IPV on survey
  ○ Definition of IPV recorded by the survey
  ○ Time points of IPV occurrence recorded (e.g., past year, lifetime, etc.)
- Applicability to populations and settings of interest

Specifically for the SRs for KQ 2, we abstracted:

- SR design features
  ○ Databases searched and search date
  ○ Study-level inclusion and exclusion criteria
  ○ Number of primary studies included for each KQ
  ○ Methods of analysis, assessment of heterogeneity, and publication bias
  ○ Strength of evidence assessment
- Results of the review
  ○ Range of mean age
  ○ Range of sex distribution
  ○ Range of race distribution for white, African American, and Hispanic
  ○ Number of studies and participants for each KQ
  ○ Synthesis of pertinent outcomes
  ○ Subgroup analysis by gender, race, or era of service
  ○ Publication bias
  ○ Sensitivity analysis
  ○ Strength of evidence
  ○ Author conclusions

## QUALITY ASSESSMENT

We abstracted data necessary to assess the quality of included studies. Across all included studies, quality criteria were applied for each study by two independent reviewers. Disagreements were resolved between the two reviewers or, when needed, by arbitration from a third reviewer. For prevalence studies, we adapted a previously published tool33 developed to assess the quality of prevalence studies. Key domains of quality assessed were selection bias, nonresponse bias, measurement bias, and biases related to analysis. Based on these criteria, a summary judgment of low, moderate, or high risk of bias was assigned to each study (Appendix C).

We also assessed the quality of SRs using criteria adapted from the AMSTAR measurement tool.34 These included the following key criteria: review assesses a focused clinical question, search methods are adequate for replication and are comprehensive, selection bias is avoided, data are abstracted reliably, characteristics of primary literature are reported and quality is assessed appropriately, results are synthesized using appropriate methods, publication bias is assessed, conflict of interest is reported, and conclusions are supported by results. Based on these criteria, SRs were categorized as good, fair, or poor quality (Appendix C). Poor-quality SRs were excluded.

## DATA SYNTHESIS

### Studies of IPV Prevalence (KQ 1)

To assess prevalence, we critically analyzed the included primary studies to compare their characteristics, methods, and findings. We then determined the feasibility of completing a quantitative synthesis (i.e., meta-analysis) by exploring the volume of relevant literature, the completeness of the results reporting, and the conceptual homogeneity of the studies. When a meta-analysis was appropriate, we used random-effects models to quantitatively synthesize the available evidence for prevalence rates. For meta-analysis, we excluded studies that were conducted in special populations, such as cohorts recruited from prenatal clinics and mental health clinics. When studies gave results only by subgroup (males, females), we combined subgroups only when the combined group represented the total study population. We estimated pooled prevalence with 95% confidence intervals (95% CIs) using a random-effects model when study designs and outcomes reported were similar.

We anticipated heterogeneity of effects; thus, we conducted subgroup analyses by key variables hypothesized to influence prevalence estimates (i.e., gender, race, IPV severity, era of service) and pooled subgroup estimates using mixed-effects models where appropriate.35 To assess if prevalence rates varied by era of service (e.g., OEF/IOF/OND), we conducted moderator analysis by date of cohort recruitment (i.e., era of cohort). Date of cohort recruitment was used as a proxy for era of service and was dichotomized as pre-2001 and post-2001.We tested for statistical heterogeneity using graphical displays and test statistics (I^2^ statistics). The I^2^ describes the percentage of total variation across studies due to heterogeneity (or inconsistency across studies) rather than to chance.36 Heterogeneity was categorized as low, moderate, or high based on I^2^ values of 25 percent, 50 percent, and 75 percent, respectively. We also conducted an influence analysis to assess the individual effects of each included study in the meta-analyses. In an influence analysis, each study is systematically removed one at a time, and a new pooled estimate is calculated to provide an estimate of the pooled prevalence without the study. When quantitative synthesis was not possible (less than three studies), we summarize findings qualitatively. All quantitative analyses were conducted using OpenMeta[Analyst] software (http://www.cebm.brown.edu/open_meta).

### Systematic Reviews of IPV Intervention Strategies (KQ 2)

Quantitative analysis of the SRs was not possible due to the limited number (n=6) and diversity of the included studies and outcomes. Instead, we grouped reviews by intervention strategy and then summarized the key characteristics, methods, and findings. If findings or conclusions differed importantly across reviews, we analyzed potential reasons for discrepancies such as review inclusion/exclusion criteria, the primary studies included, differences in outcome definition, analytic approach, and conflict of interest. When synthesizing results, we gave more qualitative weight to recent reviews of higher overall quality (e.g., good vs. fair) and to reviews that included higher quality study deigns (e.g., RCTs vs. retrospective observational studies).

## RATING THE BODY OF EVIDENCE

In addition to rating the quality of individual prevalence studies and SRs of treatment strategies, we evaluated the overall quality of the evidence for each KQ as described in the Agency for Healthcare and Research Quality's (AHRQ's) “Methods Guide for Effectiveness and Comparative Effectiveness Studies.”37 In brief, this approach requires assessment of four domains: risk of bias, consistency, directness, and precision. Additional domains considered were strength of association (magnitude of effect) and publication bias. For risk of bias, we considered basic (e.g., RCT) and detailed study design (e.g., adequate randomization). We used results from meta-analyses when evaluating consistency (forest plots, tests for heterogeneity), precision (CIs), strength of association (odds ratios), and publication bias (clinicaltrials.gov survey). These domains were considered qualitatively, and a summary rating of high, moderate, low, or insufficient strength of evidence was assigned after discussion by two reviewers. This four-level rating scale consists of the following definitions:

- High—Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate—Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low—Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect.

When a rating of high, moderate, or low was not possible or was imprudent to make, a grade of insufficient was assigned.38 We also considered the risk of publication bias. Publication bias was addressed through graphical analysis (e.g., funnel plots) for KQ 1 (prevalence of IPV) and a careful search of www.ClinicalTrials.gov (March 2013) for identification of any study completed but unpublished or ongoing for both KQs (prevalence studies and SRs on intervention strategies).

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership. A transcript of their comments can be found in the appendix, which elucidates how each comment was considered in the final report.