# INTRODUCTION

Intimate partner violence (IPV) encompasses a range of physical, sexual, or psychological harms or stalking behavior by a current or former partner across a continuum of severity. In the United States, IPV poses a significant public health burden that affects both men and women. Over a third (35.6%) of women and a fourth (28.5%) of men in the United States have experienced rape, physical violence, or stalking by an intimate partner in their lifetime.1

Outcomes associated with IPV include a wide range of social, physical, and mental issues such as family dissolution, adverse pregnancy outcomes, mental health issues (depression, posttraumatic stress disorder [PTSD], anxiety), incarceration, and death.1-5 IPV affects many facets of society including medical, mental health, social services, and criminal justice systems. Moreover, productivity losses and costs attributable to IPV are significant; estimates exceed 13.5 million workdays lost and $8.3 billion spent in the United States each year for violence perpetrated against women.6

Military service has unique psychological, social, and environmental factors that may contribute to elevated risk of IPV among active duty servicemembers and Veterans. Multiple deployments, family separation and reintegration,7 demanding workloads at home and while on duty, histories of head trauma, mental illness, and substance abuse8 can contribute to partner conflict and elevated risk of IPV among active duty servicemembers, Veterans, and their intimate partners.9-12 Several studies have estimated the prevalence of IPV among active duty servicemembers and Veterans; rates of past-year perpetration of IPV ranged from 13.3 percent to 47 percent among male active duty servicemembers and 13.5 percent to 42 percent among male Veterans.10,13-15 Thus, IPV presents a common and important problem among potential users of the VA healthcare system. Rates of IPV among military and Veteran populations likely vary by gender and race, as they do with civilian populations. Additionally, era of service may be a unique moderator of IPV prevalence among Veterans.16

Currently the VA does not have a comprehensive national program to address IPV. Thus, the VA convened the Domestic Violence Task Force to define the scope of, and design a plan for evaluating, domestic violence and IPV among Veterans. In order to support the goals and mission of this task force, the Durham VA Evidence-based Synthesis Program conducted a systemic review of the literature to synthesize the evidence on the prevalence of IPV among active duty servicemembers and Veterans and to conduct an evidence synthesis of the systematic review (SR) literature on intervention strategies to address IPV.