# PEER REVIEW COMMENTS

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | Yes, I think the goals were clear. Framework and two questions were very clear. | Thank you.
2 | Yes. This review is timely and important, especially as VHA considers how to best implement screening and treatment interventions to address this common health issue. In particular, this review highlights significant gaps in our understanding of the prevalence, impact, identification, and treatment of IPV among male and female service members and Veterans, particularly those treated in VHA. The review of the evidence for IPV screening interventions to detect IPV victimization suggests that the implementation of a systematic and comprehensive IPV screening, response and treatment programming is a critical “next step” for VHA care. The literature regarding use of aggression is less clear with respect to implications for screening and treatment within VHA, but this review certainly suggests the significant need for additional research addressing these issues in the VHA context to inform the development and implementation of these services. | Thank you.
3 | Yes. The authors have done an excellent job of searching the literature, abstracting relevant publications, reviewing the relevant publications, and presenting the summarized findings. | Thank you.
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | No, and no comments from reviewer 1. | Acknowledged
2 | No, The review does not appear biased, but I do have concerns about its comprehensiveness. For KQ2, it is unclear why the authors chose to only evaluate systematic reviews. This seems like a very limited approach as the use of systematic reviews may not capture intervention work published in recent years. Moreover, there are promising psychosocial treatments for victims and perpetrators that are supported by preliminary data that are not reflected in this review. This is a shame because VHA already has some of these treatments readily available or are in a good position to do more with these treatments (e.g., DBT skills based groups for victims, Strength at Home for perpetrators). For example, cognitive processing therapy (CPT) is effective in reducing depression and PTSD among IPV survivors and reduces risk for future IPV victimization. There is also preliminary data published by Taft et al. (2013) presenting preliminary findings on a new intervention designed specifically to reduce IPV among active duty military members and Veterans. Although this work has a small sample size, it is important to note that such evidence is being established. Similarly, the systematic reviews that evaluate screening and treatment interventions do not include a focus on empirically supported treatments for the mental health symptoms and conditions that are commonly associated with IPV victimization (e.g., PTSD). | For KQ 2, we chose to search only systematic reviews because we had identified several high quality reviews. We developed the synthesis of systematic reviews approach in collaboration with our key stakeholders, the VA Domestic Violence Taskforce. They were interested in the state of the evidence on IPV interventions across a wide area of strategies. Thus, we conducted a synthesis of recent good- or fair-quality systematic reviews in support of the VA Domestic Violence Taskforce matched to the capacity of our resources. A review of the primary intervention literature is beyond the scope of this report and the stated needs of our primary stakeholder.
2 | Additional information about the justification for methods used to estimate prevalence would be helpful. I am not an epidemiologist, but my understanding of prevalence is that it is a characteristic of a population that cannot be computed from smaller specific (i.e., clinical) samples. I am also aware that there is a dearth of nationally representative studies examining estimates of IPV in samples of Veterans, which makes it difficult to be able to answer KQ1. I would encourage the authors to provide more detail/discussion with regards to the limitations of their approach and justification regarding why they believe their prevalence estimates represent the prevalence in the full population of Veterans. It would also be helpful to include a discussion regarding the extent to which findings are generalizable to VHA patients vs. general population of Veterans. | In order to decrease heterogeneity across studies included in meta-analyses, we excluded from the quantitative analysis studies conducted in specialized populations (e.g., PTSD clinic populations, Veterans seeking family therapy counseling, gender-specific samples). This is an accepted practice in evidence syntheses. Also, we rated the risk of bias as it pertains to prevalence for each included study. The risk of bias includes questions about representativeness of the sample; studies were downgrade if they were not conducted in representative samples. However, we agree with the reviewer that there are few nationally representative studies of IPV among Veterans. Unfortunately, we did not have sufficient studies to assess subgroup differences by VHA users versus Veterans not recruited through VHA. Of the 12 studies we identified among Veteran populations, only 3 were studies conducted in national samples. Of these three studies, one study assessed only sexual violence during service and could not be included in pooled estimates, and the other study was summarized qualitatively due to insufficient homogeneous studies of IPV perpetration among Veterans. Thus, only one study with a national sampling strategy was eligible for inclusion in the meta-analyses. We conducted an influence analysis to empirically test if that study influenced the overall pooled estimates. The pooled estimate for IPV victimization both with and without this study was 35%. However, we agree that adding details to the report as it pertains to VA users versus Veteran populations not selected from VA users. We have added the number of studies recruited from VA users to our results section and also state a lack of national studies as a research gap. We also now state that results are likely more applicable to VA users in the Applicability section.
3 | No, and no comments from reviewer 3. | Acknowledged
Question 3: Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No. Were all of the studies from the National Vietnam Veterans' Readjustment Study included? | We looked for all published, peer-reviewed literature, including those conducted from the National Vietnam Veterans' Readjustment Study. At the reviewer's suggestion, we searched the NVVRS website and did not find any other eligible studies that were not previously included through the systematic review.
2 | Yes. It was unclear from the methods why certain VHA clinic/facility based studies met criteria for inclusion in the review (e.g., Sayers et al., 2009) whereas others did not (e.g., Taft, Weatherill, Woodward, Pinto, Watkins, Miller, & Dekel, 2009 for IPV perpetration; Campbell, Greeson, Bybee, & Raja, 2008 as well as Murdoch & Nichol, 1995 for IPV victimization). | We conducted a comprehensive search of the literature and developed a search strategy in collaboration with a master's-level, trained medical librarian with extensive experience in systematic review research. Of the three articles you mention, our search strategy identified two of these (Campbell, Greeson, Bybee, & Raja, 2008; Murdoch & Nichol, 1995, for IPV victimization). Murdoch & Nichol, 1995, consisted of a mixed inpatient and outpatient population. Our protocol states that we would include studies conducted in community or outpatient setting. Thus, this study was excluded. Campbell, Greeson, Bybee, & Raja, 2008 is a companion paper to our included study by Campbell & Raja, 2005. We have now added Campbell, Greeson, Bybee, & Raja, 2008 to our list of included but linked companion articles (refer to Table 3 and Appendix B). Taft, Weatherill, Woodward, Pinto, Watkins, Miller, & Dekel, 2009, was not picked up on our search. We broadened our search so that it would capture this study. In doing so we also identified two other unique studies and have included these in the final report.
2 | Similarly, what is the rationale for combining general Veteran and VHA samples into the prevalence estimate analyses? | Only one study with a national sampling strategy was eligible for inclusion in the meta-analyses. We conducted an influence analysis to empirically test if the inclusion of that study influenced the overall pooled estimates. The pooled estimate for IPV victimization both with and without this study was 35%. However, we agree that adding details to the report as it pertains to VA users versus Veteran populations not selected from VA users. We have added the number of studies recruited from VA users to our results section and also state a lack of national studies as a research gap. We also now state that results are likely more applicable to VA users in the Applicability section.
2 | Although the authors report prevalence estimates based on physical IPV, in their review of the Sayers et al. (2009) study the authors indicate that over 60% of the sample partnered, separated, or divorced Afghanistan and Iraq Veterans reported some domestic abuse in the last 6 months. (pg. 33). This study is not adequately interpreted because the 60% includes endorsement of pretty mild forms of psychological aggression (e.g., swearing at a partner), which may be an indicator of conflict as opposed to IPV. | We have added this level of detail to the results section.
2 | The authors may also be interested in the DOD-funded report that sheds some light on this question of whether active duty military women are at greater risk for IPV than their civilian counterparts (see pg. 746): http://www.sapr.mil/media/pdf/reports/FY12_DoD_SAPRO_Annual_Report_on_Sexual_Assault-VOLUME_ONE.pdf | Thank you.
2 | It was unclear why the authors indicate throughout the review that there were seven studies that assessed IPV victimization. This is misleading and implies more work has been done documenting IPV than actually exists. Three of the seven studies were excluded because they do not assess IPV. Why not just say throughout the review that there were four studies that assessed IPV? | We identified eight studies. All studies reported on some form of IPV; however, not all studies were eligible for inclusion in the meta-analysis due to heterogeneity of outcomes reported or populations surveyed. Two studies included only a highly selective form of IPV, sexual violence by an intimate partner, and were excluded from analysis. One was conducted with a population seeking VA mental health care and was considered a highly selective sample that was not amenable to meta-analysis with other broader populations.
2 | For KQ2, I was not sold on the justification for reviewing only systematic reviews on interventions. The limitations of this methodological limitation need to be fleshed out. | We have added limitation of this methodology to the Limitations section.
3 | No. Not to my knowledge. That being said, the literature search strategy may not have detected key publications that were not in the peer reviewed literature, such as government reports, etc. So, you may wish to consult with your librarian about this. | Studies had to be a peer-reviewed publication to be eligible for this review.
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | There appears to be a lot of redundancy in the report, this may be due to a set template, however the report would be more readable if redundancy were reduced (information repeated up to 3x in different sections. Several minor typos (see below), I am concerned about rating manuscripts not designed to estimate prevalence as good/fair/poor. The methodology around assessment of the SR was appropriate. P. 8 - Please check the 2013 Sourcebook on Women Veterans Healthcare – the current estimate of women using the VA is now 8%. Typos: pg 8 “repot” third paragraph; pg. 30 “as a likely was a source…” (bottom paragraph); pg. 48 “in the active duty” (should it be “on” or “during”) pg. 49 “repot” | We have reduced redundancy, when possible. We have corrected these typos. It is an established systematic review methodology to rate the methodological quality and risk of bias as it pertains to specific outcomes of interest. We used the data reported in the latest version of the Sourcebook on Women Veterans Healthcare dated October 2012 which states that 6% of Veterans using the VA in FY10 were women. However, the Sourcebook also states that the number of Veteran patients has grown by 1% each year to 8% in FY10. Thus, we now state that a range of 6% to 8% of VA users are women.
2 | The benefits of classifying studies included in the prevalence estimates and qualitative review as “poor”, “fair”, or “good” are unclear since most of these studies, particularly the clinic-based studies (i.e., Sayers et al., 2009), were not intended to investigate IPV prevalence. In addition to the need for rigorous research to evaluate IPV screening and response interventions for use of IPV, it is critical to review the evidence for psychosocial treatments that address the mental health symptoms and conditions that are associated with IPV because such treatments have implications for reducing IPV risk. For example, there is a body of work highlighting promising approaches to treating women who have experienced IPV that demonstrates improvements in health and safety. VHA has rolled out many evidence-based treatments (i.e., CPT for PTSD and Behavioral Couples Therapy for Substance Use Disorders) that may be helpful in this regard. A review of this evidence was beyond the scope of the current review, which was limited to systematic reviews of treatment interventions specifically designed for “perpetrators” or “victims”. However, such information will be critical to informing VHA treatment planning for Veterans impacted by IPV. | It is an established systematic review methodology to rate the quality and risk of bias as it pertains to specific outcomes of interest. We agree with the reviewer that an evidence synthesis of the psychosocial treatments that address the mental health symptoms and conditions associated with IPV is needed and that such a review is beyond the scope of the current report.
3 | Page 12, Figure 1. You may wish to consider omitting the line from primary IPV prevention intervention to outcomes in that the primary prevention intervention could only affect the outcome via the prevalence (or occurrence) of IPV. Page 17, Quality Assessment section. It appears that poor quality prevalence studies were included in your summary outcomes, but poor quality SRs were omitted. What is the justification for this? Page 26, Table 4, I think you may wish to change the capital Ns to non-capital n's since you are dealing with samples rather than populations. Page 27, Figure 4, you may wish to retitle this graphic to clarify that it focuses on Physical IPV perpetration (same for Figures 5 and 6, etc.). Page 29, Figure 6. You may wish to stratify this analysis based on the gender of the perpetrator. This would take into account past research which has often found that women may perpetrate IPV at higher rates than males, but males perpetrate higher rates of severe IPV (which results in greater injuries, etc.-a finding that you note on page 50). Thus, a stratified analysis may be helpful in untangling this and it could be more informative to health care providers than the current graphic on its own. | We agree and have deleted this line in the analytic framework. Poor-quality systematic reviews have serious design flaws that make the findings suspect; further, fair- and good-quality reviews were available. Poor-quality primary studies were included because of limited good-quality primary studies, and the effects of these studies on summary estimates can be readily evaluated. Thank you. We have made this change. We have added text to clarify the figure titles. The analysis is stratified by gender of the perpetrator.
3 | Page 51, Recommendations for Future Research. In this section you recommend that future reviewers of research might wish to use a similar approach as you did. However, you do not really comment on the need for more and better studies of IPV among service members and vets. You could add information on how you envision the “perfect” study given what you've found. What characteristics should it have? And make a case to potential funders why they should fund such a study. | We now have added that it is a research gap and more studies are needed in broad populations. It is beyond the scope of this review to discuss design issues as they pertain to future studies in this area.
Optional Dissemination and Implementation Questions
Question 5: Are there any clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | Yes, the report lends support to the recommendations of the VHA IPV Task Force and can inform DOD programs as well. | Thank you.
2 | National VHA Domestic Violence Task Force (Co-Chairs: Carol Sheets and Megan Gerber) | Acknowledged
3 | I do not know, but I would hope that many of them would use this information. | Acknowledged
Question 6: Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | Again, I wonder if some of the redundancies can be removed? I think it is an outstanding report, the tables are excellent for quick reference and the methodology is very strong. I would consider using a different framework to rate studies reporting prevalence. I understand the concept of restricting estimates from studies that take place in specialized settings, such as mental health clinics, however this excludes many worthwhile VA studies. No VA data is comparable in methodology to general population based data, VA data will always be “clinical” data; estimates from ill populations are always higher than that of the general population. Directions for future research can be broader as well | We have removed redundancies, when possible. We used an established framework for rating the risk of bias for included studies. We also acknowledge that several studies were excluded from quantitative synthesis. When possible and meaningful to the report, we summarized these results qualitatively. We also agree that clinical population may have different estimates than nonclinical samples. In the one analysis that included both clinical and nonclinical study samples, an influence analysis did not reveal any prevalence estimate differences. However, we have added some caveats to the report stating that most of the studies summarized in the report were from clinical populations. Last, we have broadened the future research table.
2 | See second point in comment #4. | Acknowledged
3 | Circulating the report to health care providers and others providing services to service members and vets would be an important step to solicit such ideas. | Agreed
Question 7: Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
1 | Experts on male IPV – Casey Taft and April Gerlock. You may already have asked them. Several studies did include estimate of males' victimization by female intimate partners (ie Teten 2010). | Thank you.
2 | Susan McCutcheon, National MH Director, Family Svc/Women's MH/MST, VHA ( Susan.McCutcheon@va.gov) Rachel Latta, IPV Consultant, Mental Health Services, VHA ( Rachel.Latta@va.gov) Casey Taft, IPV Content Expert, National Center for PTSD, VA Boston Healthcare System ( Casey.Taft@va.gov) | Thank you.
3 | The authors may wish to consider creating an abbreviated version of this report for publication in a peer-reviewed journal. Sometimes reports such as this one are overlooked in systematic reviews and this one certainly deserves attention. | Thank you. We plan to develop a manuscript derived from this report.