# CRITERIA USED IN QUALITY ASSESSMENT

## QUALITY ASSESSMENT FOR IPV PREVALENCE STUDIES (KQ 1)

This tool is intended to evaluate the quality of studies that examined the outcomes of prevalence of IPV. Use this risk of bias tool for the following study designs: prospective/retrospective cohort studies, case-control studies, and cross-sectional studies.

### General Instructions: Rate each question below using the response categories listed. Focus on study design and conduct, not quality of reporting. Then, after answering each item, rate the study overall as “low risk of bias” (good quality), “moderate risk of bias” (fair quality) or “high risk of bias” (poor quality) based on the following definitions

- Low Risk of Bias is a good-quality study and has the least bias, and results are considered valid. These studies will meet the majority of items in each domain.
- Moderate Risk of Bias is a fair-quality study and is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid. These studies will meet the majority of items in most but not all domains.
- High Risk of Bias is a poor-quality study with significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

1. Was the study target population a close representation of the national population in relation to relevant variables (e.g., age, sex)? Focus mainly on eligibility criteria and actual sample assembled. The target population refers to the group of people or entities to which the results of the study will be generalized. Active duty military or Veterans enrolled in VA health services is the target population.
  __Yes (LOW RISK): The study target population was a close representation of the national population.
  __No (HIGH RISK): The study target population was clearly NOT representative of the national population.
  Comments:
2. Was some form of random selection used to select the sample?
  __Yes (LOW RISK): Some form of random selection was used to select the sample (e.g., simple random sampling, stratified random sampling, cluster sampling, systematic sampling).
  __No (HIGH RISK): Some form of random selection was NOT used to select the sample.
  Comments:
3. Was the likelihood of nonresponse bias minimal?
  __Yes (LOW RISK): The response rate for the study was ≥70% [underlined: or] an analysis was performed that showed no important difference in relevant demographic characteristics or risk factors for IPV between responders and nonresponders.
  __No (HIGH RISK): The response rate was <70%, and if any analysis comparing responders and nonresponders was done, it showed a significant difference in relevant demographic characteristics or risk factors for IPV between responders and nonresponders.
  Comments:
4. Was an acceptable case definition used in the study?
  __Yes (LOW RISK): An acceptable case definition of IPV was used. An acceptable case definition clearly specifies study definition of IPV such as including type, severity, frequency, and timing.
  __No (HIGH RISK): An acceptable case definition of IPV was NOT used. Case definition of IPV lacked details to clearly define type, severity, frequency, and timing of IPV.
  Comments:
5. Was the study instrument that measured the parameter of interest (i.e., prevalence of IPV) shown to be valid and reliable?
  __Yes (LOW RISK): The study instrument was shown to have reliability and validity (e.g. test-retest, piloting, validation in a previous study). Examples of instruments with these properties include Conflict Tactics Scale, Abuse Assessment Screen.
  __No (HIGH RISK): The study instrument was NOT shown to have reliability or validity (e.g., authors developed their own untested tool).
  Comments:
6. Was the same mode (e.g., interview, self-administered questionnaire) of data collection used for all subjects?
  __Yes (LOW RISK): The same mode of data collection was used for all subjects.
  __No (HIGH RISK): The same mode of data collection was NOT used for all subjects.
  Comments:
7. Was the length of the shortest prevalence period for the parameter of interest appropriate? (Keep in mind that the longer the prevalence period, the greater the likelihood of the subject forgetting if they experienced the outcome interest.)
  __Yes (LOW RISK): The shortest prevalence period for the parameter of interest was appropriate (e.g., one-week prevalence, one-year prevalence).
  __No (HIGH RISK): The shortest prevalence period for the parameter of interest was not appropriate (e.g., lifetime prevalence).
  Comments:
8. Were the numerator(s) and denominator(s) for the parameter of interest appropriate?
  __Yes (LOW RISK): There were no errors in the reporting of the numerator AND denominator(s). The paper presented appropriate numerator(s) AND denominator(s) for the parameter of interest.
  __No (HIGH RISK): There were errors in the reporting of the numerator AND denominator(s). The paper did present numerator(s) AND denominator(s) for the parameter of interest but one or more of these were inappropriate.
  __Can't tell. (Use this option when only percentages are given.)
  Comments:
9. Were the 95% CIs for the prevalence estimates precise?
  __Yes (LOW RISK): Precise estimate (for this outcome, ± 3% is precise; e.g., corresponding to point prevalence of 15% and 12–18 as CI; ± 5% as moderately precise).
  __No (HIGH RISK): Imprecise estimate (Greater than ± 5%)
  Comments:
  Additional Comments:

Table C-1 shows the quality ratings for the IPV prevalence studies (listed alphabetically by primary article's author) included in this evidence report.

Table C-1 Quality assessment for included IPV prevalence studies^a^

Study | Overall Quality Rating | Q1 | Q2 | Q3 | Q4 | Q5 | Q6 | Q7 | Q8 | Q9
Bohannon, 1995 | Fair | Yes | No | No | Yes | Yes | Yes | Yes | Can't tell | NR
Campbell, 2003 | Fair | Yes | Yes | No | Yes | Yes | Yes | No | Can't tell | NR
Campbell, 2005 | Fair | No | Yes | Yes | No | Yes | Yes | No | Yes | NR
Caralis, 1997 | Fair | Yes | No | Yes | Yes | Yes | Yes | Yes | No | No
Coyle, 1996 | Poor | Yes | No | No | Yes | No | Yes | No | Yes | NR
Dichter, 2011 | Poor | No | Yes | No | No | No | Yes | No | Yes | NR
Dobie, 2004 | Fair | Yes | No | No | No | No | Yes | No | Yes | NR
Dutra, 2012 | Fair | Yes | No | No | Yes | Yes | Yes | Yes | Yes | No
Fonseca, 2006 | Good | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | No
Forgey, 2006 | Fair | Yes | No | No | Yes | Yes | Yes | Yes | Yes | NR
Heyman, 1999 | Good | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Luterek, 2011 | Fair | Yes | Yes | No | No | Yes | Yes | No | Yes | NR
Lutgendorf, 2009 | Fair | No | No | No | Yes | Yes | Yes | Yes | Yes | Yes
Lutgendorf, 2012 | Fair | No | No | Yes | No | Yes | Yes | Yes | Yes | NR
McCarroll, 2003 | Good | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | NR
Merrill, 1998 | Fair | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Merrill, 2005 | Fair | Yes | No | No | Yes | Yes | Yes | Yes | Can't tell | NR
Newby, 2005 | Fair | Yes | No | No | Yes | Yes | Yes | Yes | Yes | NR
O'Donnell, 2006 | Poor | No | No | No | No | Yes | Yes | No | Can't tell | NR
Rosen, 2002 | Good | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | NR
Sadler, 2003 | Fair | Yes | Yes | No | No | No | Yes | No | Can't tell | NR
Sayers, 2009 | Poor | No | No | Yes | No | No | Yes | Yes | No | No
Slep, 2010 | Good | Yes | Yes | No | Yes | Yes | Yes | Yes | Can't tell | NR
Taft, 2009 | Fair | No | No | No | Yes | Yes | Yes | Yes | Yes | No
Teten, 2009 | Fair | Yes | No | No | Yes | Yes | Yes | Yes | No | NR

a Q1=population; Q2=random selection; Q3=nonresponse bias; Q4=case definition; Q5=validity of instrument; Q6=mode of administration; Q7=time period assessed; Q8=numerator and denominator; Q9=95% confidence interval

## QUALITY ASSESSMENT FOR IPV SYSTEMATIC REVIEWS (KQ 2)

First determine whether study is a systematic review. To be a systematic review, it must include a methods section that describes (1) a search strategy and (2) an a priori approach to synthesizing the data. For reviews determined to meet the systematic review criteria, assess methodological quality.^*^

* Adapted from:

1. Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989]. 2. Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-900. [pmid: 10584742]. 3. Marinopoulos SS, Dorman T, Ratanawongsa N, et al. Effectiveness of continuing medical education. Evid Rep Technol Assess (Full Rep). 2007;(149):1-69.

### General instructions: The purpose of this rating tool is to evaluate the scientific quality of systematic reviews. It is not intended to measure the literary quality, importance, relevance, originality, or other attributes of systematic reviews

Step 1: Grade each criterion listed below as “Yes,” “No,” “Can't tell” or “Not Applicable.” Factors to consider when making an assessment are listed under each criterion. Where appropriate (particularly when assigning a “No,” or “Can't tell” score), please provide a brief rationale for your decision (in parentheses).

1. Is a focused clinical question clearly stated?
  At a minimum, the question should be developed [underlined: a priori] and should clearly identify population and outcomes. The study question does not have to be in PICO format (Population, Intervention, Comparisons, Outcomes).
  [] Yes [] No [] Can't tell [] N/A
2. Are the search methods used to identify relevant studies clearly described?
  Search methods should be described in enough detail to permit replication. The report must include search date, databases used, and search terms. (Key words and/or MESH terms must be stated and, where feasible, the search strategy should be provided.)
  [] Yes [] No [] Can't tell [] N/A
3. Was a comprehensive literature search performed?
  At least 2 electronic sources should be searched, and electronic searches should be supplemented by consulting reference lists from prior reviews, textbooks, or included studies; specialized registries (e.g., Cochrane registries); or queries to experts in the field.
  [] Yes [] No [] Can't tell [] N/A
4. Was selection bias avoided?
  Study should report the number of studies identified through searches, the numbers excluded, and give appropriate reasons for excluding based on explicit inclusion/exclusion criteria. (Look outside of the text. The number of studies excluded, etc., may be provided as a flow diagram or table.)
  [] Yes [] No [] Can't tell [] N/A
5. Was there duplicate study selection and data extraction?
  Did two or more raters make inclusion/exclusion decisions, abstract data, and assess study quality—either independently or with one rater overreading the first rater's result? Was an appropriate method used to resolve disagreements (e.g., a consensus procedure)? (If unable to make a definite decision, please mark Can't tell.)
  [] Yes [] No [] Can't tell [] N/A
6. Were the characteristics of the included studies provided?
  In an aggregated form such as a table, data from the original studies should be provided on the participants, interventions, and outcomes. The ranges of characteristics in all the studies analyzed (e.g., age, race, sex, relevant socioeconomic data, disease status, duration, severity or other diseases) should be reported. For IPV interventions, the minimum characteristics should include study ID, setting, sex (if not all one sex), intervention strategy description (or if IPV screening, screening tool and reference standard), and list of outcomes or summary of results.
  [] Yes [] No [] Can't tell [] N/A
7. Was the scientific quality of the included studies assessed and documented?
  A priori methods of assessment should be provided, and criteria used to assess study quality specified in enough detail to permit replication. It is acceptable if a review references a published scoring method (e.g., Jadad score or AHRQ).
  [] Yes [] No [] Can't tell [] N/A
8. Were the methods used to combine the findings of studies appropriate?
  For pooled results, an accepted quantitative method of pooling should be used (i.e., more than simple addition, such as a random-effects or fixed-effect model). For pooled results, a qualitative and quantitative assessment of homogeneity (Cochran's Q and/or I^2^) should be performed. If only qualitative analyses are completed, the study should describe the reasons that quantitative analyses were not completed (e.g., heterogeneity in strategies, assessment of outcomes).
  [] Yes [] No [] Can't tell [] N/A
9. Was the scientific quality of the included studies used appropriately in formulating conclusions?
  The results of the methodological rigor and scientific quality should be considered in the analysis (e.g., subgroup analyses) and the conclusions of the review, and explicitly stated in formulating recommendations.
  [] Yes [] No [] Can't tell [] N/A
10. Was publication bias assessed?
  Publication bias should be tested using a funnel plot, test statistic (e.g., Egger's regression test), or examination of ongoing registries (e.g., clinicaltrials.gov) to search for unpublished studies. If none is specified, mark Can't tell.
  [] Yes [] No [] Can't tell [] N/A
11. Was the conflict of interest stated?
  Potential sources of support should be clearly acknowledged in both the systematic review and the included studies.
  [] Yes [] No [] Can't tell [] N/A
12. Are the stated conclusions supported by the data presented?
  Were the conclusions made by the author(s) supported by the data and/or analyses reported in the systematic review?
  [] Yes [] No [] Can't tell [] N/A

Step 2: Rate the overall quality of the SR as “Good,” “Fair,” or “Poor” using the guidance below.

Good = After considering items 1-12, item 12 is rated “Yes” with no important limitations. This means that few of the items 1-12 are rated “No,” and none of the limitations are thought to decrease the validity of the conclusions. If items 3, 4, 7, or 8 are rated “no,” then the review is likely to have major flaws.

Fair = After considering items 1-12, item 12 is rated “Yes,” but with at least some important limitations. This means that enough of the items 1-12 are rated “No” to introduce some uncertainty about the validity of the conclusions.

Poor = After considering items 1-12, item 12 is rated “No.” This means that several of items 1-12 are rated “No,” introducing serious uncertainty about the validity of the conclusions.

Table C-2 shows the quality ratings for the systematic reviews included in this evidence report.

Table C-2 Quality assessment for included systematic reviews

Criteria for grading the quality of a systematic review | Ramsay, 2009 | O'Reilly, 2010 | O'Campo, 2011 | Smedslund, 2011 | Choo, 2012 | Nelson, 2012
Q1. Is a focused clinical question clearly stated? | Yes | No | Yes | Yes | Yes | Yes
Q2. Are the search methods used to identify relevant studies clearly described? | Yes | Yes | Yes | Yes | Yes | Yes
Q3. Was a comprehensive literature search performed? | Yes | Yes | Yes | Yes | Yes | Yes
Q4. Was selection bias avoided? | Can't tell | Yes | Yes | Yes | Yes | Yes
Q5. Was there duplicate study selection and data extraction? | Yes | Yes | Yes | Yes | Yes | Yes
Q6. Were the characteristics of the included studies provided? | Yes | Yes | No | Yes | Yes | Yes
Q7. Was the scientific quality of the included studies assessed and documented? | Yes | No | Yes | Yes | Yes | Yes
Q8. Were the methods used to combine the findings of studies appropriate? | Yes | Yes | Yes | Yes | Yes | NA
Q9. Was the scientific quality of the included studies used appropriately in making conclusions? | Yes | Yes | Yes | Yes | Yes | Yes
Q10. Was publication bias assessed? | NA | Can't tell | No | Yes | Yes | No
Q11. Was the conflict of interest stated? | Yes | Yes | Can't tell | Yes | Yes | Yes
Q12. Are the stated conclusions supported by the data presented? | Yes | Yes | Can't tell | Yes | Yes | Yes
Overall quality | Good | Fair | Fair | Good | Good | Good