# INCLUDED STUDIES

## IPV Prevalence Studies (KQ 1)

Table B-1 presents a key to the primary and companion articles included in the IPV prevalence studies for KQ 1, organized alphabetically by first author.

Table B-1 Primary and companion articles for KQ 1

Primary Article | Companion Article(s)
Bohannon, 1995^1^ | None
Campbell, 2003^2^ | O'Campo, 2006^3^
Campbell, 2005^4^ | Campbell, 2008^5^
Caralis, 1997^6^ | None
Coyle, 1996^7^ | None
Dichter, 2011^8^ | None
Dobie, 2004^9^ | None
Dutra, 2012^10^ | None
Fonseca, 2006^11^ | Schmaling, 2011^12^
Forgey, 2006^13^ | Forgey, 2010^14^
Heyman, 1999^15^ | Newby, 2003^16^ McCarroll, 2000^17^ McCarroll, 2010^18^
Luterek, 2011^19^ | None
Lutgendorf, 2009^20^ | None
Lutgendorf, 2012^21^ | None
McCarroll, 2003^22^ | None
Merrill, 1998^23^ | None
Merrill, 2005^24^ | Crouch, 2009^25^ Stander, 2011^26^
Newby, 2005^27^ | None
O'Donnell, 2006^28^ | None
Rosen, 2002^29^ | Rosen, 2002^30^ Rosen, 2002^31^ Rosen, 2003^32^
Sadler, 2003^33^ | None
Sayers, 2009^34^ | None
Slep, 2010^35^ | Foran, 2011^36^
Taft, 2009^37^ | None
Teten, 2009^38^ | Sherman, 2006^39^

### References Cited in Table B-1

1 Bohannon JR, Dosser DA Jr, Lindley SE. Using couple data to determine domestic violence rates: an attempt to replicate previous work. Violence Vict. 1995;10(2):133-41. [pmid: 8599598].
2 Campbell JC, Garza MA, Gielen AC, et al. Intimate Partner Violence and Abuse among Active Duty Military Women. Violence Against Women. 2003;9(9):1072-1092.
3 O'Campo P, Kub J, Woods A, et al. Depression, PTSD, and Comorbidity Related to Intimate Partner Violence in Civilian and Military Women. Brief Treatment and Crisis Intervention. 2006;6(2):99-110.
4 Campbell R, Raja S. The sexual assault and secondary victimization of female veterans: Help-seeking experiences with military and civilian social systems. Psychol Women Q. 2005;29(1):97-106.
5 Campbell R, Greeson MR, Bybee D, et al. The co-occurrence of childhood sexual abuse, adult sexual assault, intimate partner violence, and sexual harassment: a mediational model of posttraumatic stress disorder and physical health outcomes. J Consult Clin Psychol. 2008;76(2):194-207. [pmid: 18377117].
6 Caralis PV, Musialowski R. Women's experiences with domestic violence and their attitudes and expectations regarding medical care of abuse victims. South Med J. 1997;90(11):1075-1080. [pmid: 9386045].
7 Coyle BS, Wolan DL, Van Horn AS. The prevalence of physical and sexual abuse in women veterans seeking care at a Veterans Affairs Medical Center. Mil Med. 1996;161(10):588-93. [pmid: 8918119].
8 Dichter ME, Cerulli C, Bossarte RM. Intimate partner violence victimization among women veterans and associated heart health risks. Womens Health Issues. 2011;21(4 Suppl):S190-4. [pmid: 21724140].
9 Dobie DJ, Kivlahan DR, Maynard C, et al. Posttraumatic stress disorder in female veterans: association with self-reported health problems and functional impairment. Arch Intern Med. 2004;164(4):394-400. [pmid: 14980990].
10 Dutra L, de Blank G, Scheiderer E, et al. Correlates of Female Veterans' Perpetration of Relationship Aggression. Psychol Trauma. 2012;4(3):323-329.
11 Fonseca CA, Schmaling KB, Stoever C, et al. Variables associated with intimate partner violence in a deploying military sample. Mil Med. 2006;171(7):627-31. [pmid: 16895129].
12 Schmaling KB, Blume AW, Russell ML. Intimate Partner Violence and Relationship Dissolution Among Reserve Soldiers. Mil Psychol. 2011;23(6):685-699.
13 Forgey M, Badger L. Patterns of Intimate Partner Violence Among Married Women in the Military: Type, Level, Directionality and Consequences. J Fam Violence. 2006;21(6):369-380.
14 Forgey MA, Badger L. Patterns of intimate partner violence and associated risk factors among married enlisted female soldiers. Violence Vict. 2010;25(1):45-61. [pmid: 20229693].
15 Heyman RE, Neidig PH. A comparison of spousal aggression prevalence rates in U.S. Army and civilian representative samples. J Consult Clin Psychol. 1999;67(2):239-42. [pmid: 10224734].
16 Newby JH, Ursano RJ, McCarroll JE, et al. Spousal aggression by U.S. Army female soldiers toward employed and unemployed civilian husbands. Am J Orthopsychiatry. 2003;73(3):288-93. [pmid: 12921209].
17 McCarroll JE, Ursano RJ, Liu X, et al. Deployment and the probability of spousal aggression by U.S. Army soldiers. Mil Med. 2000;165(1):41-4. [pmid: 10658427].
18 McCarroll JE, Ursano RJ, Liu X, et al. Deployment and the Probability of Spousal Aggression by US Army Soldiers. Mil Med. 2010;175(5):352-356. [pmid: 20486508].
19 Luterek JA, Bittinger JN, Simpson TL. Posttraumatic Sequelae Associated with Military Sexual Trauma in Female Veterans Enrolled in VA Outpatient Mental Health Clinics. J Trauma Dissociation. 2011;12(3):261-274. [pmid: 21534095].
20 Lutgendorf MA, Busch JM, Doherty DA, et al. Prevalence of domestic violence in a pregnant military population. Obstet Gynecol. 2009;113(4):866-72. [pmid: 19305332].
21 Lutgendorf MA, Thagard A, Rockswold PD, et al. Domestic violence screening of obstetric triage patients in a military population. J Perinatol. 2012.
22 McCarroll JE, Ursano RJ, Newby JH, et al. Domestic violence and deployment in US Army soldiers. J Nerv Ment Dis. 2003;191(1):3-9. [pmid: 12544593].
23 Merrill LL, Hervig LK, Milner JS, et al. Premilitary intimate partner conflict resolution in a navy basic trainee sample. Mil Psychol. 1998;10(1):1-15.
24 Merrill LL, Crouch JL, Thomsen CJ, et al. Perpetration of severe intimate partner violence: premilitary and second year of service rates. Mil Med. 2005;170(8):705-9. [pmid: 16173214].
25 Crouch JL, Thomsen CJ, Milner JS, et al. Heterosexual intimate partner violence among Navy personnel: gender differences in incidence and consequences. Mil Psychol. 2009;21:S1-s15.
26 Stander VA, Thomsen CJ, Merrill LL, et al. Gender and Military Contextual Risk Factors for Intimate Partner Aggression. Mil Psychol. 2011;23(6):639-658.
27 Newby JH, Ursano RJ, McCarroll JE, et al. Postdeployment domestic violence by U.S. Army soldiers. Mil Med. 2005;170(8):643-7. [pmid: 16173201].
28 O'Donnell C, Cook JM, Thompson R, et al. Verbal and physical aggression in World War II former prisoners of war: role of posttraumatic stress disorder and depression. J Trauma Stress. 2006;19(6):859-66. [pmid: 17195970].
29 Rosen LN, Knudson KH, Fancher P. Intimate partner violence among U.S. Army soldiers in Alaska: a comparison of reported rates and survey results. Mil Med. 2002;167(11):ii-iii. [pmid: 12448608].
30 Rosen LN, Parmley AM, Knudson KH, et al. Gender differences in the experience of intimate partner violence among active duty U.S. Army soldiers. Mil Med. 2002;167(12):959-63. [pmid: 12502167].
31 Rosen LN, Parmley AM, Knudson KH, et al. Intimate partner violence among married male U.S. Army soldiers: ethnicity as a factor in self-reported perpetration and victimization. Violence Vict. 2002;17(5):607-22. [pmid: 12477101].
32 Rosen LN, Kaminski RJ, Parmley AM, et al. The effects of peer group climate on intimate partner violence among married male U.S. Army soldiers. Violence Against Women. 2003;9(9):1045-1071.
33 Sadler AG, Booth BM, Cook BL, et al. Factors associated with women's risk of rape in the military environment. Am J Ind Med. 2003;43(3):262-273. [pmid: 12594773].
34 Sayers SL, Farrow VA, Ross J, et al. Family problems among recently returned military veterans referred for a mental health evaluation. J Clin Psychiatry. 2009;70(2):163-70. [pmid: 19210950].
35 Slep AM, Foran HM, Heyman RE, et al. Unique risk and protective factors for partner aggression in a large scale air force survey. J Community Health. 2010;35(4):375-83. [pmid: 20373136].
36 Foran HM, Slep AM, Heyman RE, et al. Prevalences of intimate partner violence in a representative U.S. Air Force sample. J Consult Clin Psychol. 2011;79(3):391-7. [pmid: 21480693].
37 Taft CT, Weatherill RP, Woodward HE, et al. Intimate partner and general aggression perpetration among combat veterans presenting to a posttraumatic stress disorder clinic. Am J Orthopsychiatry. 2009;79(4):461-8. [pmid: 20099937].
38 Teten AL, Sherman MD, Han X. Violence between therapy-seeking veterans and their partners: prevalence and characteristics of nonviolent, mutually violent, and one-sided violent couples. J Interpers Violence. 2009;24(1):111-27. [pmid: 18378807].
39 Sherman MD, Sautter F, Jackson MH, et al. Domestic violence in veterans with posttraumatic stress disorder who seek couples therapy. J Marital Fam Ther. 2006;32(4):479-90. [pmid: 17120520].

### IPV Systematic Reviews (KQ 2)

1 Choo EK, Ranney ML, Aggarwal N, et al. A systematic review of emergency department technology-based behavioral health interventions. Acad Emerg Med. 2012;19(3):318-28. [pmid: 22435865].
2 Nelson HD, Bougatsos C, Blazina I. Screening women for intimate partner violence: a systematic review to update the U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2012;156(11):796-808. W-279, W-280, W-281, W-282. [pmid: 22565034].
3 O'Campo P, Kirst M, Tsamis C, et al. Implementing successful intimate partner violence screening programs in health care settings: evidence generated from a realist-informed systematic review. Soc Sci Med. 2011;72(6):855-66. [pmid: 21330026].
4 O'Reilly R, Beale B, Gillies D. Screening and intervention for domestic violence during pregnancy care: a systematic review. Trauma Violence Abuse. 2010;11(4):190-201. [pmid: 20688785].
5 Ramsay J, Carter Y, Davidson L, et al. Advocacy interventions to reduce or eliminate violence and promote the physical and psychosocial well-being of women who experience intimate partner abuse. Cochrane Database Syst Rev. 2009;3:CD005043. [pmid: 19588364].
6 Smedslund G, Dalsbo TK, Steiro AK, et al. Cognitive behavioural therapy for men who physically abuse their female partner. Cochrane Database of Systematic Reviews 2011, Issue 2. Art. No.: CD006048. [doi: 10.1002/14651858.CD006048.pub2]. Cochrane Database Syst Rev. 2007;3:CD006048. [pmid: 17636823].