# SEARCH STRATEGIES

## IPV Prevalence Studies (KQ 1)

Table A-1 Search strategy for PubMed (6/29/2012, updated 7/5/2012, full report 12/11/2012, updated 6/12/2013)

Set # | Terms | Results
1 | “Spouse Abuse”[Mesh] OR “Domestic Violence”[Mesh:noexp] OR intimate partner violence[tiab] OR domestic violence[tiab] OR dating violence[tiab] OR partner violence[tiab] OR domestic abuse[tiab] OR partner abuse[tiab] | 11674
2 | ((“Battered Women”[Mesh] OR “Rape”[Mesh] OR “Violence”[Mesh] OR violence[tiab]) OR ((psychological[tiab] OR emotional[tiab] OR /psychology OR physical[tiab]) AND abuse[tiab]) AND (“Spouses”[Mesh] OR sexual partners[mesh] OR marriage[mesh] OR partner[tiab] OR husband[tiab] OR wife[tiab])) | 6369
3 | #1 OR #2 | 13186
4 | prevalence[Mesh] or prevalence[tiab] or incidence[tiab] OR /statistics and numerical data OR / epidemiology OR statistics[tiab] OR rate[tiab] OR rates[tiab] OR population[tiab] | 4090541
5 | #3 AND #4 | 7216
6 | “Veterans”[Mesh] OR veteran[tiab] OR veterans[tiab] OR “Veterans Health”[Mesh] OR “Hospitals, Veterans”[Mesh] OR “Military Personnel”[Mesh] OR armed forces[tiab] OR military[tiab] OR army[tiab] OR navy[tiab] OR marines[tiab] OR marine[tiab] OR air force[tiab] OR active duty[tiab] | 119652
7 | #5 AND #6 | 134

## IPV Systematic Reviews (KQ 2)

Table A-2 Search strategy for PubMed (6/29/2012, updated 7/6/2012, full report 12/11/2012)

Set # | Terms | Results
1 | “Spouse Abuse”[Mesh] OR “Domestic Violence”[Mesh:noexp] OR intimate partner violence[tiab] OR domestic violence[tiab] OR dating violence[tiab] OR partner violence[tiab] OR domestic abuse[tiab] OR partner abuse[tiab] | 10789
2 | ((“therapy”[Subheading])) OR (therapy OR treatment OR intervention OR rehabilitation[tiab] OR prevention OR prevent[tiab] OR mass screening[mesh] OR screening[tiab] OR “Counseling”[Mesh] OR “Psychotherapy”[Mesh] OR “Mental Health Services”[Mesh] OR “Behavior Control”[Mesh]) | 7977561
3 | #1 AND #2 Filters: Systematic Reviews, English | 1404