# SUMMARY AND DISCUSSION

We evaluated palliative care integrated with oncology care for patients with symptomatic or advanced cancer, examining effects on a range of outcomes of importance to patients, clinicians, and policymakers. Our review is unique in its focus on integrated approaches for patients with advanced cancer, classification of the level of integration, and inclusion of studies that address barriers and facilitators to palliative care. We identified 7 RCTs and 2 cluster-randomized trials, all of which were comparative effectiveness trials and examined palliative care services that were moderately integrated with oncology care. We found a pattern of positive effects, including lower mortality and improved short-term QOL. Other outcomes were reported less frequently, and intervention effects could not be determined definitively.

We were particularly interested in describing intervention elements that were associated with greater benefit to patients with cancer. Most of the trials did not describe integration elements carefully. Therefore, we relied on author report to classify the level of health care integration. We qualitatively examined associations between integration elements, palliative care intervention domains, and intervention impact (based on cross-case impact analyses). There was no clear association between level of integration and intervention effects, but these analyses were limited by the small number of studies and lack of variability in integration elements. We identified and qualitatively examined 4 studies that describe barriers and facilitators to implementing integrated palliative and oncology care. Findings for each Key Question (KQ) are summarized in the sections below.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### KQ 1 Effect on Patient and Caregiver Outcomes

In all trials, palliative care interventions were delivered by multidisciplinary teams; however, aspects of the palliative care interventions (eg, intensity and level of integration) varied across trials. All interventions were colocated in the same facility and were classified as moderately integrated with palliative care services. Integrated palliative care improved short-term QOL for patients with advanced cancer. Improvements in overall symptom burden were found in all but 1 study, a finding confirmed by a meta-analysis that excluded this outlier study. Integrated palliative care decreased all-cause mortality, and among those who died, increased the likelihood of dying at home. Palliative care that included a specific caregiver intervention improved short-term caregiver depressive symptoms. Caregiver experience was improved in the single trial reporting this outcome. Palliative care did not improve other patient or caregiver outcomes or utilization outcomes; however, given that these outcomes were reported in only a small subset of studies, analyses were likely underpowered to detect effects.

Strength of evidence (SOE) was rated for primary outcomes (QOL and symptom burden) and mortality on the basis of study design, ROB, consistency, directness, and precision (Table 8). The SOE was rated high for effects on mortality and moderate for short-term QOL. SOE was low for long-term QOL and very low for overall symptom burden. SOE was not rated for adverse effects because no studies reported this outcome. Concerns that contributed to the lower SOE were high ROB and imprecision that was attributed to the 95% CI not excluding a small and small-to-moderate effect.

Table 8 Strength of Evidence for Effects of Integrated Outpatient Palliative Care and Oncology in Symptomatic or Advanced Cancer

Outcome | Number of RCTs (Patients) | Findings^a^ | Strength of Evidence (Rationale by Domain)
Quality of life, short-term (follow-up range 1 to 3 months) | 9 (1487) | SMD 0.24 higher (0.13 higher to 0.35 higher) | Moderate SOE serious ROB, consistent, precise
Quality of life, long-term (follow-up range 27 weeks to 13 months) | 5 (549) | SMD 0.15 higher (0.12 lower to 0.43 higher) | Low SOE serious ROB, consistent, imprecise
Overall symptom burden (follow-up range 1 to 3 months) | 5 (837) | SMD 0.25 lower (0.39 lower to 0.11 lower) | Very low SOE serious ROB, inconsistent, imprecise
Mortality (follow-up range 12 to 36 months) | 4 (866) | HR 0.77 (0.61 to 0.98) 96 fewer deaths per 1,000 patients (7 to 179 fewer deaths) | High SOE low ROB, consistent, precise

a SMD reported is from the sensitivity analyses excluding the single high risk of bias study.

Abbreviations: RCT=randomized controlled trial; ROB=risk of bias; SMD=standardized mean difference; SOE=strength of evidence

### KQ 2 Assessment of Integration Elements on Outcomes and Impact

Published trials of palliative care do not routinely describe elements of integration with oncology care. Integration was classified based on unpublished information from authors. We used a previously developed integration framework that classifies studies into 6 levels along a continuum of basic communication among providers to fully shared systems and resources with equal roles across providers. Data for 6 of the 9 studies were available. In these 6 trials, palliative care and oncology teams were colocated in the same facility and exchanged information in a standard and routine manner. The majority of studies involved close onsite collaboration with some systems integration; no interventions were classified as fully integrated. Regarding aspects of palliative care included in the study interventions, all interventions included physical and psychological aspects of care; none included cultural aspects of care. No association between integration level and intervention outcomes were found; however, power to detect treatment effects was limited by the small number of studies and limited variability in integration levels.

### KQ 3 Assessment of Barriers and Facilitators to Implementation

Only 4 studies addressed barriers or facilitators to integrated palliative care in VA, with only 1 study being designed specifically to address this objective. Three studies enrolled Veterans, and 1 study enrolled VA health care providers and health system leaders. Common barriers to implementation included lack of performance measures for patient-centered care and outcomes, cost of personnel, limited staffing and space, low participation by patients in shared medical appointments, and perceptions that palliative care is limited to end stages of disease. Results from 1 study found that older Veterans with advanced cancer are referred to palliative care earlier than younger Veterans. Thus, younger age among Veterans may be a barrier to either referral to and/or readiness to accept palliative care services. A patient decision aid that introduced palliative care was viewed favorably by patients and may facilitate engagement in services. Facilitators to implementation identified by VA leaders included communication and collaboration between health care leaders, and patient-provider education about roles and responsibilities of palliative and oncology teams.

## CLINICAL AND POLICY IMPLICATIONS

The VA does not have current guidelines that address provisions for standard integration of outpatient palliative care into routine oncology care. Guidelines from professional societies, including American Society of Clinical Oncology (ASCO),^8^ National Comprehensive Cancer Network (NCCN),^55^ Oncology Nursing Society (ONS),^9^ and American College of Surgeons Commission on Cancer^10^ all recommend routine integration of palliative care with oncology services. Our results, and the findings of recent systematic reviews and meta-analyses,^15,56,57^ support these recommendations in demonstrating QOL improvements with integrated care. Although we did not observe benefits for symptom burden, we are among the first to find an aggregate improvement in survival across multiple trials in the oncology setting. This effect on survival differs from a recent Cochrane review that focused narrowly on early palliative care for patients with advanced cancer. This discrepancy is related to differences in the studies evaluated: one study^58^ included in the Cochrane analysis did not meet our eligibility criteria, and some studies included in our analyses were either not published at the time of the Cochrane review^45^ or were excluded from their review.^39^ Negative outcomes (eg, 6-12 month QOL, caregiver well-being) outside of the short-term setting should be interpreted with caution, given the shorter-term focus of most trials in this area. Our findings suggest an important role for consistent integration of palliative care into routine outpatient oncology care, which should be considered in applicable policies and clinical practices in VA. Similar to the recent Cochrane Review,^56^ we were not able to isolate care components or integration elements associated with greater intervention effect.

## LIMITATIONS

Our protocol-driven review has a number of strengths, including input from an expert panel, new data gathered from study authors, rigorous methods, examination of barriers and facilitators to implementation, and a novel approach to evaluating the key elements of integrated palliative care. This novel approach allowed for a theory-driven, standardized classification of each study intervention. A significant limitation of this approach is that we relied on authors' retrospective reports about aspects of integration that were used to classify each study. Additionally, a broad definition of colocation (ie, in the same facility) was used and limited variability in author responses to this item. Thus, it is possible that degree of the physical proximity was diverse and could account for some variability in the impact ratings. Further, all of the included studies described interventions as being colocated, and a non-colocated intervention was not available for comparison. We limited our review to English-language publications, which may have excluded potentially informative evidence. Other limitations are described below.

### Publication Bias

Given the small number of studies, statistical methods to detect publication bias are not useful. Other strategies, such as searching ClinicalTrials.gov for completed but unpublished studies is not a particularly effective way to identify publication bias. Thus, although no publication bias was detected, tools for detection are poor.

### Study Quality

We were also limited by the existing literature. We identified few studies, and several were assessed as unclear ROB. High attrition and incomplete data, inadequate or unclear allocation concealment, and outcome assessments that were not clearly blinded to intervention assessment within trials contributed to judgments of higher risk. Palliative care intervention components and integration elements were poorly defined in most studies; 3 of the 9 study authors did not respond with information about integration elements. Some outcomes of interest, such as caregiver outcomes, were infrequently reported. No studies reported adverse effects.

### Heterogeneity

We compared interventions that varied substantially in goals, delivery, intensity, and target recipient. We found that interventions varied in intensity, frequency of contact, duration, delivery mode, goals, and outcome measures used. Despite variability in intervention design characteristics, effects on most outcomes were consistent. We also compared outcome measures that may not have precisely measured the same constructs, though we attempted to pool only measures that were conceptually similar. Additionally, although no intervention effect was found on long-term quality of life, research has not examined the appropriateness of this outcome for patients in the late stages of terminal illness. Thus, it is unclear whether long-term quality of life would be expected to increase as patients approach death.

### Applicability of Findings to VA Population

Two (22%) of the 9 studies examining the effects of integrated palliative and oncology care and 3 (75%) of the 4 studies describing barriers and facilitators to implementation of integrated care included Veteran samples. Eleven studies were conducted in North America, and the other 2 studies were conducted in economically developed countries. Identified studies included predominantly white samples, and it is unclear whether the findings generalize to individuals from other ethnic and racial groups.

## RESEARCH GAPS/FUTURE RESEARCH

We structure our reflection of gaps in evidence by considering each element of the PICOT framework (Table 9). Although it would be possible to generate an extensive list of gaps in evidence, we restricted this list to the areas judged to be highest priority, given the current state of evidence. To facilitate future literature syntheses, we encourage investigators conducting clinical trials to include these studies in trial registries.

Table 9 Highest Priority Evidence Gaps

PICOT Domain | Evidence Gap
Population | Research needed with ethnically, racially, socioeconomically diverse groups of people. Evaluate potential differential intervention effects by type of malignancy.
Interventions | More clearly defined integration elements and aspects of intervention are needed. More clearly defined methods could reduce uncertainty about the relationship between outcomes and intervention dose, mode of delivery, and components. Study designs are needed to incorporate patient and caregiver/stakeholder input on barriers and facilitators to implementation.
Comparators | Inpatient palliative care may also be considered as a comparator; non-colocated integrated care interventions could also be compared to colocated integrated care interventions.
Outcomes | Few studies report caregiver outcomes. Outcome measures vary greatly across studies making synthesis difficult. Research is needed on outcomes most valued by patients with advanced cancer, and how to best measure these outcomes, including the respondent (patient or caregiver) and measures that account for the unique characteristics of this population.
Timing | Short-term outcomes may be most useful for this patient population.
Setting | Research on integration between palliative and oncology care in community settings is needed. VA and other funding agencies may consider a comparative effectiveness trial.

The VHA may be uniquely well-suited to addressing these gaps in evidence. A key component of the Quality Enhancement Research Initiative (QUERI) program^59^ is to advance implementation science and identify effective strategies for implementing effective interventions. Our review supports integrated palliative care as an effective intervention, and thus it is well-suited to a test of implementation strategies. However, palliative care does not appear to be a particularly good fit into any of the 15 existing QUERI Centers, so to pursue this, it is likely a new QUERI Center would need to be formed to focus on this issue. QUERI has also developed innovative partnerships between health services investigators and program offices in VA to evaluate the effectiveness of new programs and initiatives. Partnerships in this area would have the potential to test the effects of real-world implementation of integrated palliative care and to conduct evaluations to better identify the key components of palliative care and integration that are associated with the most effective programs.

## CONCLUSIONS

There is a small but growing literature about integrated palliative and oncology care interventions for patients with symptomatic or advanced cancer. Overall, we identified a diverse set of interventions that showed moderate levels of integration. These interventions demonstrated a pattern of small-to-moderate, positive short-term effects on mortality and on outcomes that are important to patients. Effects on other outcomes, such as health care utilization and caregiver outcomes, are less well studied. However, considerable gaps remain in the evidence for critical intervention elements and some policy-relevant outcomes. More clearly defined palliative care intervention characteristics and integration elements would allow for a more precise understanding of the impact of integrated palliative and oncology care on outcomes. New studies should report both intervention elements and integration elements more carefully, adopt a standard set of outcomes, and attend to recruiting from a more racially and ethnically diverse population.