# RESULTS

## LITERATURE FLOW

Figure 1 shows the flow of articles through the literature search and review process. The search identified 1,916 unique citations from a combined search of MEDLINE^®^ (via PubMed^®^), CINAHL and the Cochrane Central Register of Controlled Trials. An additional 72 articles were identified from manual searches of bibliographies of systematic and narrative reviews and current literature published after the search date for a total of 1,988 unique citations. After applying inclusion and exclusion criteria at the title only screening level, 700 were promoted to full abstract screening. After applying criteria at the full-abstract level, the citations were culled down to 196 articles for full-text review. Of these, 13 studies and 11 companion papers were retained for data abstraction. Appendix H presents a study characteristics table detailing all studies included in KQs 1 and 2 of this report; the results section contains a descriptive table of the KQ 3 studies.

Figure 1 Literature Flow Diagram

## KEY QUESTION 1 In patients with symptomatic or advanced cancer, what are the benefits and harms of integrated outpatient palliative and oncology care compared with usual oncology care?

### Key Points

- In 9 trials, integrated palliative care was delivered by multidisciplinary teams in outpatient settings, but the intensity of interventions varied considerably.
- Most studies enrolled a majority of white men and women with multiple types of advanced cancer at a median of 8 to 12 weeks following diagnosis or recurrence.
- Integrated palliative care improved short-term (SMD 0.24; 95% CI 0.13 to 0.43) but not longer-term patient QOL (SMD 0.15; 95% CI -0.12 to 0.43).
- Integrated palliative care decreased overall mortality (HR 0.77; 95% CI 0.61 to 0.98). These effects were consistent across the 4 studies reporting this outcome.
- When excluding an outlier study, overall symptom burden improved modestly, but there was no effect when evaluating all studies. Psychological symptoms did not improve with palliative care but were reported in only a subset of studies.
- Palliative care that included a specific caregiver intervention improved short-term depressive symptoms in caregivers. Caregiver experience was improved in the single trial reporting this outcome. In 3 trials, caregiver QOL was not improved.
- Utilization outcomes were inconsistently measured. Of those studies that assessed utilization, palliative care increased the likelihood of dying at home but did not reduce overall patterns of health care utilization. However, confidence intervals were wide, suggesting low statistical power.
- No studies reported on adverse events or harms of integrated palliative care in patients with advanced cancer.

### Detailed Findings for KQ 1

We identified 9 trials comparing integrated outpatient palliative and oncology care to oncology care.^12,14,39-45^ Most studies enrolled patients with several types of advanced cancer; the median time from diagnosis or recurrence was 8 to 12 weeks. Most studies were conducted in the United States, 2 enrolled Veterans,^12,41^ and 2 used cluster-randomization.^40,42^ Palliative care was compared to standard oncology care in 6 trials. Single trials compared palliative care to oncology care plus a symptom-management toolkit,^40^ oncology care plus “on-demand” palliative care,^39^ and delayed palliative care that began 3 months postrandomization.^41^ The ROB for objective outcomes was judged low for 3 studies,^12,14,42^ unclear for 3 studies,^39-41^ and not applicable for the 3 studies not reporting these outcomes.^43-45^ ROB for patient-reported outcomes was judged low for 2 studies,^12,45^ unclear for 4 studies,^14,41,42,44^ and high for the other studies. Table 2 shows the evidence profile for the 9 studies. Detailed study characteristics are reported in Appendix G.

Table 2 Evidence Profile for Integrated Palliative Care Studies (N=9)

Study designs | 7 RCTs 2 cluster RCTs
Study years | 2006-2017
Median number of patients enrolled (range) | 207 (115-461)
Total number of patients enrolled | 2,088
Mean patient age (range) | 64.3 (59-67) reported in 8 studies
Median percentage female (range) | 45.1% (31.5%-71.2%)
Median percentage white (range) | 94.4% (84.9%-96.5%) reported in 6 studies
Number of studies with Veterans | 2
Median time since diagnosis or recurrence (range) | 8-12 weeks (30-60 days to 12 months)
Intervention setting | 7 ambulatory 2 home
Cancer diagnoses | 7 multiple cancers 1 lung cancer 1 pancreatic cancer
Patients' functional status | 4 studies: ECOG 0-2 5 studies: not reported
Countries | 7 USA 1 Canada 1 Europe
Risk of bias, objective outcomes | 3 low 3 unclear 3 not applicable
Risk of bias, patient-reported outcomes | 2 low 4 unclear 3 high

CRT=cluster-randomized trial; ECOG=Eastern Cooperative Oncology Group; RCT=randomized controlled trial

### Palliative Care Interventions

All palliative care interventions in the included studies addressed physical and psychological symptoms (Appendices D and F). Most interventions also addressed social, spiritual, ethical and legal needs. End-of-life care and structural issues were addressed explicitly in half of the interventions, but cultural issues were not addressed explicitly in any studies. All but 1 study described the palliative care clinicians.^39^ Palliative care services were delivered by a multidisciplinary team of 2 to 5 clinicians; all included nurses, 5 included a palliative care physician, 3 included a mental health professional (medical social worker, psychologist, or licensed clinical social worker and psychiatrist or psychologist), and 2 included chaplains. All studies provided services during outpatient visits; 4 also included telephone-based care, and 3 described delivery of written materials. One study used telephone as the primary method of intervention delivery.^12^ Palliative care services were delivered for a median of 17 weeks in studies with a specified duration; 3 studies continued the intervention until death with a maximum follow-up of 4 years. The intensity of services varied greatly, ranging from 4 sessions weekly^12^ to contacts every 2 to 4 weeks until death.^39^

Integration between palliative care and oncology services was rarely described, but 6 of the 9 authors responded to our request for information. In all trials for which the authors responded, palliative care services were colocated in the same facility with oncology services. Standard communication about specific treatment issues, interactive communication, and routine communication exchanges between palliative care and oncology clinicians were reported in at least half the studies (Figure 2). Integration elements of the palliative care interventions are described in more detail in KQ 2.

Figure 2 Clinical Domains and Integration Elements of the Interventions

#### Effects on Functional Status, Overall Symptom Burden, and Psychological Symptoms

All studies reported short-term (1-3 months) effects of integrated palliative care on QOL. Integrated palliative care improved QOL (SMD 0.24; 95% CI 0.13 to 0.35; I^2^=0%; Q=6.9; p=0.55) (Figure 3). Positive effects were consistent, ranging from small to moderate benefit in all but 1 study. In the 6 studies reporting longer-term effects at 6-12 months, QOL was not improved (SMD 0.15; 95% CI -0.12 to 0.43; I^2^=28%; Q=5.6; p=0.23), with estimates from individual studies clustering around no effect (Figure 4). One study found an interaction effect, showing greater effects of palliative care for patients with lung cancer than those with gastrointestinal cancer.^45^ Of note, longer-term QOL was not a primary study endpoint in any of these studies, and study dropout due to death and disease progression likely limited the ability to detect longer-term differences in outcomes. Additionally, it might be expected that longer-term QOL would be expected to decrease as symptom burden increases and end of life nears.

Figure 3 Short-term (1-3 months) Effects of Integrated Palliative Care on QOL

Abbreviations: CI=confidence interval; FACIT-PAL=Functional Assessment of Chronic Illness Therapy-Palliative Care; FACIT-Sp=Functional Assessment of Chronic Illness Therapy-Spiritual Well-Being; FACT-G=Functional Assessment of Cancer Therapy-General; FACT-Hep=Functional Assessment of Cancer Therapy-Hepatobiliary; N=study sample size; QOL=quality of life; ROB=risk of bias; SD=standard deviation; SMD=standardized mean difference; TOI=Trial Outcome Index

Figure 4 Long-term (6-12 months) Effects of Integrated Palliative Care on QOL

Abbreviations: CI=confidence interval; FACIT-PAL=Functional Assessment of Chronic Illness Therapy-Palliative Care; FACIT-Sp=Functional Assessment of Chronic Illness Therapy-Spiritual Well-Being; FACT-G=Functional Assessment of Cancer Therapy-General; FACT-Hep=Functional Assessment of Cancer Therapy-Hepatobiliary; N=study sample size; ROB=risk of bias; QOL=quality of life; SD=standard deviation; SMD=standardized mean difference; TOI=Trial Outcome Index

Effects of integrated palliative care on overall symptom burden were reported in 6 studies (Figure 5). At 1 to 3 months postrandomization, patients assigned to integrated palliative care showed small but statistically nonsignificant improvements in symptom burden (SMD -0.17; 95% CI -0.45 to 0.11; I^2^=62%; Q=13.2; p=0.022). A seventh study^44^ only reported effects on symptom burden as statistically nonsignificant and so could not be included in the meta-analysis; omitting this study from the meta-analysis may bias the estimate of effect.

Figure 5 Effects of Integrated Palliative Care on Overall Symptom Burden

Abbreviations: CI=confidence interval; ESAS=Edmonton Symptom Assessment Scale; FACT-L=Functional Assessment of Cancer Therapy-Lung; HCS: Hepatobiliary Cancer Subscale; LCS=Lung cancer subscale; N=study sample size; QUAL-E= Quality of life at end of life symptom impact subscale; ROB=risk of bias; SD=standard deviation; SDS=Symptom Distress Scale; SMD=standardized mean difference

All but one study^41^ showed small-to-moderate improvement in symptom burden. This outlier study, judged unclear ROB, was conducted in 3 settings, including a VA medical center, and did not include longitudinal in-person visits with specialist palliative care clinicians. After an in-person consultation by a board-certified palliative care clinician, an advanced practice nurse delivered structured coaching sessions by telephone, with 3 sessions that included attention to symptom management. A sensitivity analysis that excludes this study shows a consistent pattern of decreased symptom burden with integrated palliative care (SMD -0.25; 95% CI -0.39 to -0.11; I^2^=0%; Q=3.8; p=0.43).

Effects of integrated palliative care on one or more psychological symptoms were reported in all but 1 study.^42^ Six studies reported the effects on depression symptoms.^12,14,39-41,45^ There was no short-term effect of the intervention on depressive symptoms in the 4 studies reporting severity as a continuous outcome (SMD -0.09; 95% CI -0.32 to 0.13; Q=2.8; p=0.43, I^2^=0%) (Figure 6). One^14^ of 2 studies^14,39^ reporting the proportion meeting the threshold for depressed mood showed an intervention effect (n=104; 4% vs 17% meeting criteria for major depression; p=0.04).

Figure 6 Effects of Integrated Palliative Care on Depressive Symptoms

Abbreviations: CES-D=Center for Epidemiologic Studies Depression Scale; CI=confidence interval; PC=palliative care; PHQ=Patient Health Questionnaire; N=study sample size; ROB=risk of bias; SD=standard deviation; SMD=standardized mean difference

Two studies^14,39^ reported the proportion of patients with significant anxiety symptoms; neither showed a difference between the palliative care and oncology care groups. Two studies^43,44^ reported effects on transient mood states using the Profile of Mood States, which assesses tension or anxiety, anger or hostility, vigor or activity, fatigue or inertia, depression or dejection, and confusion or bewilderment. Neither study showed a statistically significant effect. In summary, there was no consistent pattern of beneficial effects on psychological symptoms.

#### Effects on Survival

Four studies reported effects on overall mortality.^12,14,39,41^ Overall mortality was reported at 12 months in 2 studies,^39,41^ a mean of 14.6 months in 1 study,^12^ and at 4.5 to 36 months follow-up in another.^14^ We used hazard ratios reported by the study or estimated hazard ratios from reported data. Two studies were judged low ROB^12,14^ and 2 were unclear ROB for this outcome. All studies compared integrated palliative care to usual oncology care except for Bakitas et al (2015), in which the control patients began delayed palliative care 3 months postrandomization. Integrated palliative care was associated with lower all-cause mortality (HR 0.77; 95% CI 0.61 to 0.98; I^2^=0%; Q=2.3; p=0.52) (Figure 7).

Figure 7 Effects of Integrated Palliative Care on All-Cause Mortality

Abbreviations: CI=confidence interval; HR=hazard ratio

#### Effects on End-of-Life Care

Death at home was reported in 3 trials (567 patients) with follow-up ranging from 6 to 35 months.^14,39,41^ Patients who received palliative care were more likely to die at home (RR 1.19; 95% CI 1.05 to 1.36; I^2^=0%; Q=0.2; p=0.93) (Figure 8). Effects on site of death were consistent across studies.

Figure 8 Risk of Dying at Home with Palliative Care

Abbreviations: CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

Aggressiveness of care near the end of life was reported in 3 trials,^14,41,42^ but measures varied greatly. Thus, we synthesized these results qualitatively. One study judged low ROB^14^ that was conducted in patients with lung cancer reported a composite measure, which was considered met for any patient who had at least 1 of the following: chemotherapy 14 days before death, no use of hospice care, or admission to hospice 3 days or less before death. Palliative care patients were less likely than those assigned to usual oncology care to receive aggressive end-of-life care on this composite outcome (33% vs 54%; p=0.05). Three studies judged low ROB reported chemotherapy use at end of life,^14,41,42^ only 1 of which showed an intervention effect (chemotherapy in the last 60 days of life, 32/61 vs 47/67; p=0.05).^14^ One study reported on the proportion of patients receiving chemotherapy at all,^42^ while the other reported receipt of chemotherapy in the last 60 days of life^41^; neither showed an intervention effect. Only 1 study reported the proportion of patients receiving radiotherapy^42^; there was no intervention effect. In summary, intervention effects on end-of-life care were inconsistent. While the interventions consistently had an impact on the likelihood of dying at home, most studies did not report measures of aggressiveness in care at the end of life; among those that did, only 1 study showed an intervention effect.

#### Effects on Health Care Utilization

Measures of utilization were not reported in all trials, and when present were not reported consistently across studies. Thus, we synthesized these results qualitatively. Emergency department use was reported in 4 of 6 trials.^12,14,39,41^ No intervention effects were noted in any study, but in the 3 studies reporting the proportion of patients with an emergency department visit, visits were modestly lower (risk ratio range 0.73 to 0.93). Hospitalization data were also reported in these 4 studies, with no apparent intervention effect.^12,14,39,41^ Again, hospitalization rates were modestly lower (risk ratio range: 0.73 to 0.96) in the 3 studies reporting this rate. For both emergency department visits and hospitalizations, the estimates of effect were imprecise and do not exclude a clinically important effect. Only 2 studies reported intensive care unit utilization^12,41^; there was no apparent intervention effect.

Costs of care were reported in only 1 study of patients with lung cancer.^14^ The intervention was associated with a lower mean total cost per day throughout the entire study period, but this difference was not statistically significant ($117; p=0.13). Costs for the provision of chemotherapy in the last 30 days of life were significantly different, with the intervention yielding a $757 mean reduction compared to the standard care arm (p=0.03). In summary, only a minority of trials reported utilization data, and measures were inconsistent and not planned primary outcome measures in any studies. While these limited data do not demonstrate an intervention effect, studies do not appear to be powered to detect small-to-moderate effects on utilization.

#### Effects on Other Outcomes

Caregiver experience was reported in 3 trials (2 companions).^41-43,46,47^ The best data come from a cluster-randomized trial judged unclear ROB that enrolled 461 patients with advanced cancers, and reported caregiver experience using a measure that assessed satisfaction with information-giving, availability of care, psychological care, and physical care (range 16-80 with higher scores better).^42^ Only 182 caregivers participated due to unavailability of caregivers, declining to participate, or not completing baseline measures. The intervention involved a consultation and follow-up in the oncology palliative care clinic by a palliative care physician and nurse. Visits occurred monthly and were supplemented by telephone support as needed. For patients assigned to palliative care, caregiver experience was better at 3 months (mean change 1.4 vs -3.1; p=0.007; SMD 0.39; 95% CI 0.02 to 0.77, calculated by review authors) and 4 months (mean change 0.6 vs -2.4; p=0.02; SMD 0.27; 95% CI -0.10 to 0.65, calculated by review authors). Caregiver quality of life did not differ between groups. Two other trials (1 companion)^41,43,47^ reported on caregiver quality of life, which may be related to (but does not directly measure) caregiver experience. Both trials used the Quality of Life Index-Cancer Scale, a 35-item self-report measure assessing physical, emotional, spiritual, and family dimensions of well-being. Palliative care was delivered by a multidisciplinary team and was designed to address multiple domains of QOL. One study incorporated a telephone-based intervention for caregivers addressing multiple topics such as the role of the caregiver, problem-solving, self-care, effective partnering, building a support team, decision support, and advance care planning. There were no intervention effects in either study at 3 months^41,47^ or 27 weeks.^43^ Collectively, 3 trials showed no benefit of integrated palliative care on caregiver QOL.

A single study (1 companion) reported effects of palliative care on caregiver depressive symptoms and caregiver burden.^41,48^ Caregivers were enrolled for about 60% of the participating patients. Outcomes were assessed at 3 months, at which time the comparison group was eligible for palliative care and in the subset where the care recipient died, at 8 to 12 weeks after death. At 3 months postrandomization, depressive symptoms were lower (mean difference -3.4 on the Center for Epidemiological Studies Depression Scale, standard error 1.5; Cohen's d -0.32; p=0.02) for caregivers randomized to early palliative care. Of the 70 caregivers eligible for post-death assessment, 44 (63%) responded. There was no effect on depressive symptoms (Cohen's d 0.07; p=0.88) or grief (Cohen's d -0.21; p=0.51). Caregiver burden was measured with the 14-item Montgomery-Borgatta Caregiver Burden Scale, which included objective, demand, and stress burden subscales. At 3 months, there were no intervention effects on any of the 3 caregiver burden subscales (Cohen's d -0.01 to 0.09; p≥0.29). In an analysis confined to caregivers whose care recipient had died, stress burden (Cohen's d -0.44; p=0.01), but not demand or objective burden, was lower in caregivers assigned to early palliative care.

Patient experience was reported in the cluster-randomized trial, using the same multidimensional measure completed by caregivers.^42^ For patients assigned to palliative care, patient experience was better at 3 months (mean difference 3.8, 95% CI 1.74 to 5.85; Cohen's d 0.47). These benefits were greater at 4 months (mean difference 6.0, 95% CI 3.94 to 8.05; Cohen's d 0.73).

Adverse effects of integrated palliative care were not specified as an outcome and were not reported in any trials.

### Quality of Evidence for KQ 1

The ROB for objective outcomes was judged low for 3 studies,^12,14,42^ unclear for 3 studies,^39-41^ and not applicable for the other 3 studies (Figures 9 and 10). ROB for patient-reported outcomes was judged low for 2 studies,^12,45^ unclear for 4 studies,^14,41,42,44^ and high for the other studies. Patterns that led to judgments of higher ROB included (1) inadequate or unclear allocation concealment (n=6), (2) outcome assessments that did not clearly blind to intervention assignment (n=6), and (3) incomplete outcome data (n=3). Cluster-randomization by oncology specialty (eg, lung vs gastrointestinal malignancy)^40^ also could have affected results. If palliative care has differential effects by cancer diagnoses, then this randomization strategy would confound results. Another factor may be the comparator: 1 study used “on-demand” palliative care in the control arm but did not report how often these services were delivered.^39^ Another study used delayed palliative care as the comparator,^41^ which would serve to narrow intervention effects on palliative care services that were offered to the control arm.

Figure 9 Risk of Bias Ratings for Each Study^a^ a Empty cells indicate items that were not applicable.

Figure 10 Summary Ratings Across Studies for Each ROB Domain^a^ a White space indicates items that were not applicable.

## KEY QUESTION 2 Which features of integrated palliative and oncology care are associated with greater benefit to patients with symptomatic or advanced cancer?

### Key Points

- Published trials of palliative care do not routinely describe elements of integration with oncology care. Classifying integration required author queries for additional data.
- Of 9 trials, 2 were classified as having basic collaboration onsite and 4 as having close collaboration onsite with some systems integration. Three studies could not be classified due to missing information.
- We did not identify an association between integration level and overall intervention effects or effects on short-term quality of life. However, these analyses were limited by the small number of studies and the limited range of integration levels.

### Detailed Findings for KQ 2

We used the Integrated Practice Assessment Tool (IPAT)^19^ to classify the level of collaboration and integration for each trial. The IPAT identifies 6 levels of collaboration and integration. The key element of integration for Levels 1 and 2 is communication, with the distinction between Level 1 and Level 2 being the frequency and type of communication. Physical proximity is the key element for Levels 3 and 4, with Level 4 requiring some degree of shared systems. The key element of Levels 5 and 6 is practice change, with the highest level being characterized by a joint patient treatment plan, balanced and shared resources, equal roles in patient care, and providers being involved in care in a standard way across all patients. After classifying the level of integration for a trial, we used quantitative and qualitative approaches to examining associations between integration and intervention effects.

#### Levels of Integration

Elements of integration were rarely described in the publications, and available data on integration elements was based primarily on retrospective report from authors. Data on integration were supplied by authors from 6 of the 9 trials.^12,14,40-42,45^ Using these data, the IPAT decision tree model was used to cascade each trial to a specific level of integrated health care (Table 3). The level of integration showed little variability across studies. Two trials^12,42^ were classified Level 3 Integration (Basic Collaboration Onsite), and 4 studies ^14,40,41,45^ were classified Level 4 integration (Close Collaboration Onsite with Some Systems Integration). Palliative care and oncology teams were physically or virtually located at the same facility across all trials—but not necessarily colocated in the same clinical space. Authors of all trials endorsed exchanging information between palliative care and oncology teams as a standard and routine practice, and all but 1 trial involved routine exchange of written or electronic information.^14^ With the exception of one trial,^41^ all trials involved bidirectional, interactive communication between palliative care and oncology teams. Palliative care and oncology teams were involved in care in a standard way across all providers and patients in only 3 trials,^40,41,45^ all of which were the most recently published trials. Palliative care and oncology teams had equal roles in decision making in only 1 trial,^14^ and only 1 trial involved a joint treatment plan for patients.^41^

Table 3 Levels of Integration and Impact Ratings for Integrated Palliative and Oncology Care

Study^a^ | Integration Elements | | | | | | | Level of integration Impact rating^b^
Study^a^ | Care teams colocated? | Written or electronic information exchanged routinely? | Care teams communication bidirectional? | Information exchanged as standard and routine practice? | Care providers have equal roles in decision making? | Care standardized across ALL patients? | One joint treatment plan for cancer patients? | Level of integration Impact rating^b^
Bakitas, 2009^12^ | Yes | Yes | Yes | Yes | No | No | No | Level 3 Moderate
Bakitas, 2015^41^ | Yes | Yes | Unsure | Yes | No | Yes | Yes | Level 4 Low
Clark, 2013^43^ | No author response | | | | | | | Unclear Low
Maltoni, 2016^39^ | No author response | | | | | | | Unclear Low
McCorkle, 2015^40^ | Yes | Yes | Yes | Yes | No | Yes | No | Level 4 None
Rummans, 2006^44^ | No author response | | | | | | | Unclear Low
Temel, 2010^14^ | Yes | No | Yes | Yes | Yes | No | No | Level 4 Moderate
Temel, 2017^45^ | Yes | Yes | Yes | Yes | Unsure | Yes | No | Level 4 Low
Zimmermann, 2014^42^ | Yes | Yes | Yes | Yes | No | No | No | Level 3 Low

a Answers were solicited from the first author of each article. Report investigators also answered questions based on reading the published article; however, with only 1 exception, the report investigators' answer was always unsure.

b Impact ratings range from none to high and are independently derived based on a judgment about intervention effects (eg, effect size or statistical significance) across 6 outcome domains.

#### Association Between Integration Classes, Intervention Elements, and Intervention Effects

Impact ratings were assigned after considering intervention effects on 6 outcome categories. Six trials^39,41-45^ were classified as “low impact,” 2 trials^12,14^ as “moderate impact,” and 1 trial as “no impact.”^40^ The limited number of studies, and the limited variability in integration levels and impact ratings, precluded quantitative analyses to examine the association between integration levels and intervention impact. Qualitative analysis of this association identified no consistent pattern of results. Trials with Level 4 integration ratings had impact ratings of low,^41,45^ moderate,^14^ and none.^40^ The 2 trials with Level 3 integration ratings^12,42^ included all of the same elements of integration but had different impact ratings (moderate and low, respectively).

All trials included 3 of the elements of integration: colocation, standard and routine information exchange, and routine exchange of written or electronic information. These integration elements did not appear to be associated with a greater benefit for patients given that impact ratings ranged from none to moderate across the 6 trials. Authors of the studies were asked about integration elements with a “yes/no/unsure” response option. Thus, specific information about communication and colocation was not available, and it is possible that degree of physical proximity and frequency and method of information exchange was diverse and could account for some variability in the impact ratings.

Three of the 7 elements measured (ie, equal roles in decision making; providers involved in care in a standard way across all patients; having one joint patient treatment plan) are among the required elements for Integration Levels 5 (Close Collaboration Approaching an Integrated Practice) and 6 (Full Collaboration in a Transformed/Merged Integrated Practice). Only one of these 3 elements was related to a higher impact rating. Specifically, one trial^14^ involved equal roles in decision-making among palliative care and oncology providers and had a moderate impact rating. In contrast, when all other elements of communication and colocation were equal across trials, those trials that included standardized care across all patients, 1 joint patient treatment plan, or both, had impact ratings of no^40^ or low.^40-42,45^ Further, 1 trial^12^ that included none of these higher-level integration elements had a moderate impact rating. These results may suggest that palliative care and oncology teams that have interactive, routine, and written or electronic communication and some degree of colocation more greatly benefit patients with cancer than teams that additionally have 1 joint patient treatment plan and a standard approach to care across all patients.

Among the 6 trials for which there were data on level of integration, the relation between integration level and effects of the intervention on short-term QOL (1-3 months) was examined quantitatively (Figure 11). Quantitative analysis was possible for this outcome, specified a priori as a primary outcome, because it was reported in all trials. Overall, there was no association between level of integration and intervention effects on short-term QOL. Two of the 6 studies^14,42^ had a significant positive effect on short-term QOL, and both studies included the following 3 elements of integration: (1) interactive, bidirectional communication, (2) standard and routine information exchange, and (3) colocation.

Figure 11 Integration Category and Effects on Short-term QOL

Abbreviations: CI=confidence interval; N=study sample size; QOL=quality of life; ROB=risk of bias; SD=standard deviation

In addition to elements of integration, we assessed the association between palliative care intervention elements (the 8 domains of structure, physical, psychological, social, spiritual, cultural, end of life, ethical/legal^29^) and the overall impact of the intervention (Table 4). No clear pattern of association between palliative care domains and impact ratings emerged. All trial interventions involved physical (ie, interdisciplinary assessment and management of pain and other physical symptom needs) and psychological (ie, psychological and psychiatric assessment and treatment of patient-family and staff needs including grief and bereavement services) aspects of palliative care as this was a requirement for inclusion in the review. All trials except one^39^ involved the social aspects of palliative care (ie, person-centered interdisciplinary assessment to identify and promote the patient-family strengths, needs, and goals). None of the study interventions described cultural aspects of palliative care (ie, assessment of patient-family cultural needs and service in a culturally and linguistically appropriate manner). The 2 studies with the highest impact ratings^12,14^ both included end-of-life (ie, interdisciplinary team attends to patient-family values, preferences, beliefs, culture, and religion to promote a peaceful and dignified death and post-death plan for support) and ethical/legal (ie, plan of care based on patient-surrogate goals preferences, and choices are respected within the limits of applicable state and federal law) aspects of care. One of these studies^14^ included structural processes (ie, involvement of a specialty-trained palliative care interdisciplinary team striving for best practices inclusive of quality assessment and performance improvement) and spiritual (ie, interdisciplinary assessment and respectful attention to patient-family religious, spiritual, or cultural practices before, at, and after death) aspects of care while the other did not.^12^ Overall, trials that included more aspects of palliative care than others did not appear to have higher impact ratings. Similarly, no constellations of specific aspects of palliative care were found to relate to impact ratings in a meaningful way.

Table 4 Palliative Care Intervention Domains and Impact Ratings

Study | Structural | Physical | Psychological | Social | Spiritual | Cultural | End of Life | Ethical/L egal | Impact Rating^a^
Bakitas, 2009^12^ | No | Yes | Yes | Yes | No | No | Yes | Yes | Moderate
Bakitas, 2015^41^ | No | Yes | Yes | Yes | Yes | No | Yes | Yes | Low
Clark, 2013^43^ | No | Yes | Yes | Yes | Yes | No | No | Yes | Low
Maltoni, 2016^39^ | Yes | Yes | Yes | No | Yes | No | No | No | Low
McCorkle, 2015^40^ | Yes | Yes | Yes | Yes | No | No | No | Yes | None
Rummans, 2006^44^ | No | Yes | Yes | Yes | Yes | No | Yes | No | Low
Temel, 2010^14^ | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Moderate
Temel, 2017^45^ | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Low
Zimmermann, 2014^42^ | Yes | Yes | Yes | Yes | No | No | No | No | Low

a Impact ratings range from none to high and are independently derived based on a judgment about intervention effects (eg, effect size or statistical significance) across 6 outcome domains.

### Quality of Evidence for KQ 2

Elements of integration were rarely described in the manuscripts, and all authors were contacted to obtain information about the degree to which trials included the 7 elements of integration measured in this review. Six authors responded with information; however, authors were reporting retrospectively and were, in some cases, unsure about details of the studies (some of which were conducted nearly a decade ago). Thus, the nature of integration element measurement impacts the validity and quality of the data.

## KEY QUESTION 3 What are the most common and important barriers to implementing integrated palliative and oncology care in Veterans Affairs settings?

### Key Points

- Few studies directly addressed common and important barriers to implementing integrated palliative and oncological care in the VHA.
- Common barriers to implementation included low participation rates to shared appointments, perceptions that palliative care is meant to be used later in the disease trajectory, and poor communication and coordination among providers and patients.
- Facilitators to implementation included greater collaboration among local leaders within a health care system, improved patient-centered care, and patient-provider education about roles and responsibilities of care both in oncology and palliative care services.

### Detailed Findings for KQ 3

We identified 4 studies^49-52^ addressing barriers to integrated palliative care in VA. However, only 1 study was designed specifically to address this objective.^50^ The study designs included qualitative, mixed-methods, and retrospective chart review; 3 of the studies enrolled Veterans and 1 study enrolled health care providers and health system leaders from the VHA. All studies were conducted in the United States (Table 5). Detailed study characteristics are reported in Table 6. The ROB was judged low for all studies.^49-52^

Table 5 Study Characteristics for KQ 3 Studies

Study | Design | Study Population | Intervention and Comparator | Total N | Mean Age | % Female | Setting
Bakitas, 2016^49^ | Mixed-methods summative evaluation | Advanced solid tumor or hematological malignancy (prognosis 6-24 months) who were recently diagnosed and caregivers defined as “someone who knows you well and is involved in your medical care” | N=57; early palliative care telehealth (6 weekly sessions) using a patient decision aid N=20 caregivers (3 weekly sessions) | 77 | 64 (10.4) | 63% N=52 | National Cancer Institute-designated cancer center, VA medical center, and outreach clinics
Bekelman, 2016^50^ | Cross-sectional; qualitative semi-structured interviews | Health care providers and local, regional, and national health system leaders from the VHA | NA | 17 | NR | NR | VHA
Maloney, 2013^51^ | Qualitative descriptive study RCT; in-depth, semi-structured interviews | Newly diagnosed advanced or recurrent lung, gastrointestinal, genitourinary, or breast cancer | N=27; original study included multicomponent psychoeducational intervention N=26; usual care | N=53 (1 participant interview was lost due to technical difficulties) | 63.3 (11.1) | 52.8% N=28 | VA hospital outpatient clinic
Sharma, 2016^52^ | Retrospective chart review | Veterans with advanced cancer who died between 2002 and 2009 | N/A | N=567 ≥ Age 65=372 Age 40-64=195 | ≥ Age 65=75.8 (6.69) Age 40-46=57.7 (4.76) | ≥Age 65=3.8% N=14 Age 40-46= 4.1% N=8 | VA medical center

#### Patient Perspectives of Palliative Care Services

One study investigated the benefits and burdens of a palliative care intervention implemented at time of the diagnosis in 53 Veterans.^51^ Using qualitative thematic analysis, 4 themes emerged regarding the benefits of the palliative care intervention: (1) enhanced problem-solving, (2) better coping, (3) feeling empowered in health care choices and dealing with friends and family, and (4) feeling supported, reassured, and hopeful. Barriers to trial participation were completing questionnaires and being reminded about illness by participation. Barriers relevant to implementing palliative care were lack of attendance by other participants to shared medical appointments and the perception that the palliative care intervention did not apply until later in the diagnosis.

#### Utilization of Palliative Care

Utilization of palliative care in Veterans who died of advanced cancer was assessed in 1 retrospective study.^52^ Utilization of palliative care services was defined as the mean number of days of referral to hospice before death, and mean length of stay in hospice before death. Utilization of acute care services was defined as a composite outcome of emergency room visits, hospital admission, and intensive care unit (ICU) admission. Older Veterans (≥65 years of age; n=372) were referred to palliative care earlier than younger Veterans (40-65 years of age; n=195) (47.3 vs 34.5 days, p=0.015), and older Veterans spent more time in hospice (32.5 vs 20.2 days, p=0.007). There was no difference found between older and younger Veterans who declined PC. Older Veterans had fewer hospital admissions (p=0.043) and ICU admissions (p=0.030). During the last month of life, the odds of having at least one emergency room visit, hospital admission, or ICU visit did not differ between younger and older Veterans.

#### Utilization of Patient Decision Aid in Palliative Care

One mixed-method study judged at low ROB^49^ assessed the utilization of the commercial decision aid “Looking Ahead: Choices for Medical Care When You're Seriously Ill” (Health Dialog Services Corporation, 2007) in 57 patients and 20 caregivers participating in an RCT of early palliative care.^41^ The patient decision aid included a 60-page booklet and 37-minute video. The majority of patients (93%) and all caregivers recommended the patient decision aid. Ninety-three percent of patients and 95% of caregivers watched the video. Forty-six percent of patients read all or most of the book. Seventy-two percent of the patients recommended that the program be received at time of diagnosis, while 14% recommend prior to diagnosis and 14% recommended when treatment is no longer working. Three themes emerged regarding patient-reported impact of the patient aid: (1) feeling empowered and informed to question health care providers, (2) becoming aware of different options (such as palliative care and hospice care), and (3) engaging in advance care planning and recognizing the importance of including family members in decisions.

#### Organizational Barriers and Facilitators to Implementing Outpatient Palliative Care

Organizational factors related to implementing outpatient palliative care services in VA was assessed in one study.^50^ In a cross-sectional qualitative study, 17 VA health care providers from multiple clinical disciplines and health care leaders including chiefs of service, regional, and national leaders, completed semi-structured interviews. The domains of the Consolidated Framework for Implementation Science^53^ were used to identify barriers and facilitators to implementing outpatient palliative care. Five themes related to barriers and facilitators of implementation emerged: (1) develop performance measures for patient-centered care and outcomes that can be used to measure the quality and incentivize the spread of outpatient palliative care, (2) justify additional personnel cost and assess and address practical issues such as staffing and space prior to implementation, (3) communication and coordination with other providers and coordination should be tailored to local and individual preferences, (4) collaborate with local leaders to determine how outpatient palliative care aligns with local programs and needs, and (5) clarify the roles and responsibilities of outpatient palliative care versus primary and specialty care for disease management in advanced chronic illness, and structure core components of outpatient palliative care to allow for flexibility during implementation.

#### Summary

This review yielded a small number of eligible studies to answer KQ 3. Overall, barriers to implementing integrated palliative and oncological care in the VHA potentially include age, shared medical appointment format, timing of palliative care services (some patients early in the illness may not be ready), lack of performance measures relevant to patient-centered care and outcomes of early palliative care, cost of personnel, staffing, and limited space for service delivery. Potential facilitators to implementation include decision aids and shared decision-making process, planned communication and coordination between health care team, flexibility in core clinical components, and elements of palliative care rated highly by patients that may help “sell” providers. Performance measures relevant to patient-centered care and outcomes of early palliative care may also be a potential facilitator to implementation; however, in the VHA there are currently no standardized performance measures.

### Quality of Evidence for KQ 3

The ROB was judged low for all studies.^49-52^ Detailed ROB descriptions are given in Tables 6 and 7.

Table 6 ROB for KQ 3 Studies with Qualitative Designs^32^

Study | Clear Statement of Aims | Appropriate Qualitative Method | Appropriate Research Design | Appropriate Recruitment Strategy | Data Collected Addressed Research Issue | Sufficiently Rigorous Data Analysis | Overall Risk of Bias
Maloney, 2013^51^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Bakitas, 2016^50^ | Yes | Yes | Yes | Yes | Yes | Yes | Low
Bekelman, 2016^50^ | Yes | Yes | Yes | Yes | Yes | Yes | Low

Table 7 ROB for KQ 3 Study with Retrospective Cohort Design^31,32,54^

Study | Selection of exposed and nonexposed drawn from the same population | Confident in assessment of exposure | Confident that outcome of interest was not present at start of study | Exposed and nonexposed matched for all variables or controlled for prognostic variables | Confident in assessment of prognostic factors | Confident in assessment of outcome | Adequate follow up of cohorts | Cointerventions were similar between groups | Overall Risk of Bias
Sharma, 2016^52^ | Definitely Yes | Definitely Yes | Definitely Yes | Mostly Yes | Definitely Yes | Definitely Yes | Definitely Yes | NA | Low