# REFERENCES

1 Siegel RL, Miller KD, Fedewa SA, . Colorectal cancer statistics, 2017. CA Cancer J Clin. 2017; 67(3):177-193.28248415
2 Kroenke K, Zhong X, Theobald D, Wu J, Tu W, Carpenter JS. Somatic symptoms in patients with cancer experiencing pain or depression: prevalence, disability, and health care use. Arch Intern Med. 2010; 170(18):1686-1694.20937930
3 Center to Advance Palliative Care. Definition of palliative care. Available at: https://www.capc.org/about/palliative-care/. Accessed July 28, 2017.
4 von Gunten CF, Lupu D. Development of a medical subspecialty in palliative medicine: progress report. J Palliat Med. 2004; 7(2):209-219.15130199
5 Institute of Medicine. Delivering High-Quality Cancer Care: Charting a New Course for a System in Crisis. National Academies Press (US): Washington, DC. 2013.
6 American Board of Internal Medicine. Hospital and Palliative Medicine Policies. Available at: http://www.abim.org/certification/policies/internal-medicine-subspecialty-policies/hospice-palliative-medicine.aspx. Accessed July 14, 2017.
7 Smith TJ, Temin S, Alesi ER, . American Society of Clinical Oncology provisional clinical opinion: the integration of palliative care into standard oncology care. J Clin Oncol. 2012; 30(8):880-887.22312101
8 Ferrell BR, Temel JS, Temin S, . Integration of Palliative Care Into Standard Oncology Care: American Society of Clinical Oncology Clinical Practice Guideline Update. J Clin Oncol. 2017; 35(1):96-112.28034065
9 Oncology Nursing Society. Position statements. Available at: https://www.ons.org/advocacy-policy/positions. Accessed July 26, 2017.
10 American College of Surgeons. Cancer program standards. Available at: https://www.facs.org/quality-programs/cancer/coc/standards. Accessed July 26, 2017.
11 National Comprehensive Cancer Network. NCCN Guidelines for Palliative Care. Available at: https://www.nccn.org/about/news/ebulletin/ebulletindetail.aspx?ebulletinid=130. Accessed July 14, 2017.
12 Bakitas M, Lyons KD, Hegel MT, . Effects of a palliative care intervention on clinical outcomes in patients with advanced cancer: the Project ENABLE II randomized controlled trial. JAMA. 2009; 302(7):741-749.19690306
13 Bakitas M, Stevens M, Ahles T, . Project ENABLE: a palliative care demonstration project for advanced cancer patients in 3 settings. J Palliat Med. 2004; 7(2):363-372.15130218
14 Temel JS, Greer JA, Muzikansky A, . Early palliative care for patients with metastatic non-small-cell lung cancer. N Engl J Med. 2010; 363(8):733-742.20818875
15 Kavalieratos D, Corbelli J, Zhang D, . Association Between Palliative Care and Patient and Caregiver Outcomes: A Systematic Review and Meta-analysis. JAMA. 2016; 316(20):2104-2114.27893131
16 Gomes B, Calanzani N, Curiale V, McCrone P, Higginson IJ. Effectiveness and cost-effectiveness of home palliative care services for adults with advanced illness and their caregivers. Cochrane Database Syst Rev. 2013(6):CD007760.
17 Center to Advance Palliative Care. Growth of Palliative Care in US Hospitals: 2015 Snapshot (2000–2013). Available at: https://www.google.com/url?sa=t&rct=j&q=&esrc=s&source=web&cd=1&ved=0ahUKEwistfCnhYnVAhVCSyYKHbs9D6AQFggkMAA&url=https%3A%2F%2Fmedia.capc.org%2Ffiler_public%2F34%2F77%2F34770c03-a584-4079-a9ae-edb98dab6b20%2Fgrowth_snapshot_2016_final.pdf&usg=AFQjCNHBb8USyMnPXqAZDUzAG2FqoSjixg&cad=rja. Accessed July 14, 2017. 2013.
18 Hui D, Elsayem A, De la Cruz M, . Availability and integration of palliative care at US cancer centers. JAMA. 2010; 303(11):1054-1061.20233823
19 Waxmonsky J, Auxier A, Wise Romero P, Heath B. Integrated Practice Assessment Tool (IPAT). 2013. Available at: http://www.integration.samhsa.gov/operations-administration/IPAT_v_2.0_FINAL.pdf. Accessed July 14, 2017.
20 Heath B, Wise Romero P, Reynolds K. A Standard Framework for Levels of Integrated Healthcare. Washington, D.C.SAMHSA-HRSA Center for Integrated Health Solutions. March 2013. Available at: http://www.integration.samhsa.gov/integrated-care-models/A_Standard_Framework_for_Levels_of_Integrated_Healthcare.pdf?goback=%2Egde_4254769_member_229362523. Accessed July 14, 2017.
21 Kaufmann TL, Kamal AH. Oncology and palliative care integration: cocreating quality and value in the era of health care reform. J Oncol Pract. 2017:JOP2017023762.
22 Hui D, Bruera E. Models of integration of oncology and palliative care. Ann Palliat Med. 2015; 4(3):89-98.26231806
23 Hui D, Kim YJ, Park JC, . Integration of oncology and palliative care: a systematic review. Oncologist. 2015; 20(1):77-83.25480826
24 Kamal AH, Currow DC, Ritchie CS, Bull J, Abernethy AP. Community-based palliative care: the natural evolution for palliative care delivery in the US J Pain Symptom Manage. 2013; 46(2):254-264.23159685
25 Meier DE, Beresford L. Outpatient clinics are a new frontier for palliative care. J Palliat Med. 2008; 11(6):823-828.18715171
26 DiMartino LD, Weiner BJ, Mayer DK, Jackson GL, Biddle AK. Do palliative care interventions reduce emergency department visits among patients with cancer at the end of life? A systematic review. J Palliat Med. 2014; 17(12):1384-1399.25115197
27 Lorenz KA, Lynn J, Dy SM, . Evidence for improving palliative care at the end of life: a systematic review. Ann Intern Med. 2008; 148(2):147-159.18195339
28 Singer AE, Goebel JR, Kim YS, . Populations and Interventions for Palliative and End-of-Life Care: A Systematic Review. J Palliat Med. 2016; 19(9):995-1008.27533892
29 National Consensus Project for Quality Palliative Care. Clinical Practice Guidelines for Quality Palliative Care (ed 3). 2013. Pittsburgh, PA. Available at: https://www.hpna.org/HPNA_Item_Details.aspx?ItemNo=978-1-934654-35-4. Accessed July 19, 2017.
30 Higgins JPT, Altman DG, Gøtzsche PC, . The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343.
31 Wells GA, Shea B, O'Connel D. The Newcastle-Ottawa scale (NOS) for assessing the quailty of nonrandomised studies in meta-analyses. Available at: https://www.google.com/url?sa=t&rct=j&q=&esrc=s&source=web&cd=2&ved=0ahUKEwjTldKmqInVAhXH6CYKHbC8A2EQFggrMAE&url=https%3A%2F%2Fwww.ncbi.nlm.nih.gov%2Fbooks%2FNBK99082%2Fbin%2Fappb-fm4.pdf&usg=AFQjCNFFkGagLWH-3qPWOFcPI9C2qee_Xw&cad=rja. Accessed July 14, 2017.
32 Critical Appraisal Skills Programme (CASP). CASP Qualitative Checklist. Available at: http://www.casp-uk.net/casp-tools-checklists. Accessed July 14, 2017.
33 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986; 7(3):177-188.3802833
34 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003; 22(17):2693-2710.12939780
35 Sterne JA, Sutton AJ, Ioannidis JP, . Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002.21784880
36 Miles MB, Huberman AM, Saldana J. Qualitative Data Analysis: A Methods Sourcebook. Sage Publications. 1994.
37 Rubenstein LV, Williams JW, Jr., Danz M, Shekelle P, Suttorp M, Johnsen B. Determining Key Features of Effective Depression Interventions. 2009. VA Evidence-based Synthesis Program Reports. Available at: https://www.hsrd.research.va.gov/publications/esp/depinter.cfm. Accessed July 14, 2017.
38 Agency for Healthcare Research and Quality (AHRQ). Methods Guide for Effectiveness and Comparative Effectiveness Reviews [Internet]. 2008. Available at: https://www.effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&mp=1&productID=318. Accessed March 29, 2017.
39 Maltoni M, Scarpi E, Dall'Agata M, . Systematic versus on-demand early palliative care: results from a multicentre, randomised clinical trial. Eur J Cancer. 2016;65:61-68.27472648
40 McCorkle R, Jeon S, Ercolano E, . An advanced practice nurse coordinated multidisciplinary intervention for patients with late-stage cancer: a cluster randomized trial. J Palliat Med. 2015; 18(11):962-969.26305992
41 Bakitas MA, Tosteson TD, Li Z, . Early versus delayed initiation of concurrent palliative oncology care: patient outcomes in the ENABLE III randomized controlled trial. J Clin Oncol. 2015; 33(13):1438-1445.25800768
42 Zimmermann C, Swami N, Krzyzanowska M, . Early palliative care for patients with advanced cancer: a cluster-randomised controlled trial. Lancet. 2014; 383(9930):1721-1730.24559581
43 Clark MM, Rummans TA, Atherton PJ, . Randomized controlled trial of maintaining quality of life during radiotherapy for advanced cancer. Cancer. 2013; 119(4):880-887.22930253
44 Rummans TA, Clark MM, Sloan JA, . Impacting quality of life for patients with advanced cancer with a structured multidisciplinary intervention: a randomized controlled trial. J Clin Oncol. 2006; 24(4):635-642.16446335
45 Temel JS, Greer JA, El-Jawahri A, . Effects of early integrated palliative care in patients with lung and GI cancer: a randomized clinical trial. J Clin Oncol. 2017; 35(8):834-841.28029308
46 McDonald J, Swami N, Hannon B, . Impact of early palliative care on caregivers of patients with advanced cancer: cluster randomised trial. Ann Oncol. 2016.
47 Dionne-Odom JN, Azuero A, Lyons KD, . Benefits of early versus delayed palliative care to informal family caregivers of patients with advanced cancer: outcomes from the ENABLE III randomized controlled trial. J Clin Oncol. 2015; 33(13):1446-1452.25800762
48 Dionne-Odom JN, Azuero A, Lyons KD, . Family caregiver depressive symptom and grief outcomes from the ENABLE III randomized controlled trial. J Pain Symptom Manage. 2016; 52(3):378-385.27265814
49 Bakitas M, Dionne-Odom JN, Jackson L, Frost J, Bishop MF, Li Z. “There were more decisions and more options than just yes or no”: Evaluating a decision aid for advanced cancer patients and their family caregivers. Palliat Support Care. 2016:1-13.26857749
50 Bekelman DB, Rabin BA, Nowels CT, . Barriers and Facilitators to Scaling Up Outpatient Palliative Care. J Palliat Med. 2016; 19(4):456-459.26974489
51 Maloney C, Lyons KD, Li Z, Hegel M, Ahles TA, Bakitas M. Patient perspectives on participation in the ENABLE II randomized controlled trial of a concurrent oncology palliative care intervention: benefits and burdens. Palliat Med. 2013; 27(4):375-383.22573470
52 Sharma N, Sharma AM, Wojtowycz MA, Wang D, Gajra A. Utilization of palliative care and acute care services in older adults with advanced cancer. J Geriatr Oncol. 2016; 7(1):39-46.26769146
53 Damschroder LJ, Aron DC, Keith RE, Kirsh SR, Alexander JA, Lowery JC. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implement Sci. 2009;4:50.19664226
54 Guyatt G, Busse J. Methods commentary: risk of bias in cohort studies. Evidence Partners. Available at: https://www.evidencepartners.com/resources/methodological-resources/risk-of-bias-in-cohort-studies/. Accessed July 26, 2017.
55 Levy M, Smith T, Alvarez-Perez A, . Palliative Care Version 1.2016. J Natl Compr Canc Netw. 2016; 14(1):82-113.26733557
56 Haun MW, Estel S, Rucker G, . Early palliative care for adults with advanced cancer. Cochrane Database Syst Rev. 2017;6:CD011129.
57 Davis MP, Temel JS, Balboni T, Glare P. A review of the trials which examine early integration of outpatient and home palliative care for patients with serious illnesses. Ann Palliat Med. 2015; 4(3):99-121.26231807
58 Tattersall M, Martin A, Devine R, . Early Contact with Palliative Care Services: A Randomized Trial in Patients with Newly Detected Incurable Metastatic Cancer. J Palliat Care Med. 2014; 4(1):1-6.
59 US Department of Veterans Affairs. QUERI program. Available at: https://www.queri.research.va.gov/about/default.cfm. Accessed July 26, 2017.