# METHODS

## TOPIC DEVELOPMENT

This evidence report was commissioned to (1) evaluate the effects of palliative care, initiated “upstream,” and integrated with oncology care for patients with cancer, (2) describe intervention characteristics associated with greater benefit, and (3) describe common barriers to implementing integrated palliative care into Veterans Affairs (VA) settings.

The key questions (KQs) for this systematic review were developed after a topic refinement process that included a preliminary review of published peer-reviewed literature, consultation with internal partners and investigators, and consultation with content experts and key stakeholders at the Association of VA Hematology/Oncology, Palliative Care Research Committee, the Office of Patient Care Services' Geriatrics and Extended Care Program, and the Hospice and Palliative Care Program.

The final KQs were:

KQ 1: In patients with symptomatic or advanced cancer, what are the benefits and harms of integrated outpatient palliative and oncology care compared with usual oncology care?

KQ 2: Which features of integrated palliative and oncology care are associated with greater benefit to patients with symptomatic or advanced cancer?

KQ 3: What are the most common and important barriers to implementing integrated palliative and oncology care in VA settings?

We followed a standard protocol for this review, and each step was pilot-tested to train and calibrate study investigators. The PROSPERO registration number is CRD42017057541.

## SEARCH STRATEGY

In consultation with an expert librarian, we conducted searches of MEDLINE (via PubMed), the Cochrane Central Register of Controlled Trials, and CINAHL through November 21, 2016, for KQ 1 and KQ 2; through January 19, 2017, for KQ 3. We evaluated the bibliographies of systematic or nonsystematic reviews for relevant studies. We used a combination of MeSH keywords and selected free-text terms to search titles and abstracts. In addition, we reviewed the bibliographies of recent applicable reviews and contacted subject matter experts to identify additional studies.^15,16,26-28^ All citations were imported into 2 electronic databases (for referencing, EndNote^®^ Version X7, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada). The exact search strategies used are in Appendix A.

## STUDY SELECTION

Using prespecified eligibility criteria (Appendix B), 2 reviewers independently evaluated titles and abstracts to identify potentially eligible studies. Key eligibility criteria were randomized controlled trials (RCTs) or quasi-experimental studies evaluating integrated palliative and oncology care in adults with symptomatic advanced cancer; interventions delivered in outpatient settings that addressed at least the physical symptom and psychosocial components of care; integration as evidenced by some degree of real-time communication between oncologist and palliative care team; and patient-reported QOL, survival, or health care utilization outcomes reported ≥28 days after enrollment. Because details of integrated care were routinely absent from the published literature, we provisionally included all studies meeting other eligibility criteria and attempted to contact all authors for missing information to inform final eligibility decisions. Four of 7 authors responded to these requests. When the information from the author differed from what could be ascertained from the article alone, this information was added. Studies addressing KQ 3, barriers to implementation, had to be conducted in the VHA or be related to a study included for KQ 1 and both quantitative and qualitative study designs were included. Articles included by either reviewer underwent full-text screening by 2 independent reviewers; disagreements were resolved by discussion or by a third investigator. Articles meeting eligibility criteria were included for data abstraction. Appendix C contains a list of excluded studies and the reason for exclusion.

## DATA ABSTRACTION

Study characteristics including patient characteristics, intervention/comparator details, quality elements, and outcomes were abstracted into a customized DistillerSR database. To capture shorter- and longer-term effects, we abstracted outcomes at 2 timepoints: postintervention (±1 month) and at least 6 months' postintervention. For studies with multiple assessments at greater than 6 months postintervention, we abstracted the last available assessment. Because of diverse study designs, we abstracted data on barriers/facilitators to implementation of integrated palliative care into a structured report form that captured study design, population characteristics, key findings. All abstractions were overread by a second reviewer. Disagreements were resolved by discussion or by a third reviewer.

## CATEGORIZATION OF THE INTERVENTIONS

We categorized the interventions along 2 dimensions: (1) 8 clinical elements of palliative care (eg, addressing physical and psychological symptoms) based on the Clinical Practice Guidelines for Quality Palliative Care as described by the National Consensus Project^29^ (Appendix D) and (2) 7 elements of integrated care (eg, colocation, communication^19,20^) as measured by the Integrated Practice Assessment Tool (IPAT),^19^ which is based on the Substance Abuse and Mental Health Services Administration's standard framework for levels of integrated health care.^20^ The IPAT classifies practices into 6 levels, ranging from minimal collaboration to full collaboration in an integrated, colocated practice. The 6 levels are grouped as coordinated care (Levels 1 and 2), colocated care (Levels 3 and 4), and integrated care (Levels 5 and 6). In addition, we described the clinical disciplines delivering care and the mode of intervention delivery. Because information about integration was missing or unclear, we contacted the primary author for clarification; authors responded to our survey for 6 of the 9 studies (Appendix E). We used data from the authors and manuscripts to classify integration along a 6-level spectrum from “minimal collaboration” to “full collaboration in an integrated practice.”

## QUALITY ASSESSMENT

Quality assessment was completed independently by 2 investigators; disagreements were resolved by consensus or by arbitration from a third reviewer. We used the Cochrane risk of bias (ROB) tool for RCTs.^30^ These criteria are adequacy of randomization and allocation concealment; comparability of groups at baseline; blinding; completeness of follow-up and differential loss to follow-up; whether incomplete data were addressed appropriately; and validity of outcome measures. For studies addressing implementation barriers, we used the revised Newcastle Ottawa Scale for cohort studies^31^ and adapted the Critical Appraisal Checklist for qualitative studies.^32^ We assigned a summary ROB score (low, moderate, or high) to individual studies.

## DATA SYNTHESIS

We described the included studies using summary tables and graphical displays. We computed summary effects (ie, meta-analysis) when studies were conceptually homogeneous and there were at least 3 studies with the same outcome. We grouped outcomes into similar measurement windows (eg, 1-3 months after enrollment, 4-6 months after enrollment).

Some studies reported dichotomous outcomes (eg, survival) and some studies reported continuous outcomes (eg, QOL) or both. When quantitative synthesis was possible, we combined dichotomous outcomes using random-effects models and hazard ratio, risk ratio, or odds ratio as appropriate. Continuous outcomes were summarized using the standardized mean difference because outcomes were assessed with different measures for the same construct (eg, QOL). For analyses with few (n <20) studies, we used the Knapp-Hartung approach to adjust the standard errors of the estimated coefficients.^33,34^ Sensitivity analyses included analyses that omitted studies judged to be at high ROB or that included only studies with relatively robust measures of the outcome. We evaluated for statistical heterogeneity using visual inspection and Cochran's Q and I^2^ statistics. Publication bias was could not be assessed statistically because there were fewer than 10 studies in all analyses.^35^

We used a force-rank methodology that included presentation of initial rankings to stakeholders and study coinvestigators, followed by discussion, to identify the intervention and integration elements hypothesized to be associated with greater intervention effects. We used 2 rounds of iterative prioritization to select 5 intervention and 2 integration components for moderator analyses. Two of the intervention components (physical and psychosocial) were eligibility criteria and thus present in all studies. When meta-analyses were feasible, with sufficient studies to support subgroup analyses of moderator variables, we evaluated the consistency of intervention effects on QOL outcomes by elements of the prioritized intervention and integration elements. Because subgroup analyses that involve indirect comparisons (across studies) are subject to confounding, we interpreted results of these moderator analyses cautiously.

When quantitative synthesis was not feasible, we synthesized intervention effects qualitatively. We gave more weight to the evidence from higher quality studies with more precise estimates of effect. We analyzed potential reasons for inconsistency in treatment effects across studies by evaluating differences in the study population, intervention, comparator, and outcome definitions.

## QUALITATIVE SYNTHESIS

After reviewing quantitative results, we used qualitative cross-case impact analysis iteratively to refine our results and develop a short list of key intervention features.^36^ To carry out the analyses, we ranked studies by impact level (see below). We then analyzed the relationship of intervention and integration elements with intervention impacts using tables and graphical displays. We focused on the elements prioritized by the stakeholders and study team as key components of successful interventions. We analyzed the pattern of associations by individual elements and holistically, using the 6-level categorization of integration described previously.

Because different studies reported different outcomes using different scales, each outcome (eg, QOL, symptom burden) was included in only a subset of studies. To create an outcome measure applicable to all articles in the set, we developed an impact rating scale, an approach used previously to identify key intervention elements of collaborative care for depression.^37^ To derive the impact measure, we randomly ordered the studies on a spreadsheet and listed only each study's set of outcomes, without any identifiers. We listed all the measured outcomes for each study that fell into 1 of 6 conceptual domains: QOL, symptom burden, mortality, site of death, cancer treatment at end of life, and resource utilization. Two investigators (JF, TC) considered the outcomes reported for each study and independently rated the intervention impact on a 4-point scale. Initial agreement was substantial (weighted kappa=0.4), and disagreements were resolved by discussion and consensus.

The studies were rated high, moderate, or low impact. High impact studies had to show a pattern of positive effects across all patient-centered outcomes. Moderate impact studies showed patterns of mostly positive effects across patient-centered outcomes. Low impact studies had inconsistent patterns of statistically positive and negative effects across patient-centered outcomes. All might have positive effects on end-of-life care and/or utilization. Studies deemed to have “no impact” reported all patient-centered outcomes as statistically nonsignificant. The data we used to make these determinations as well as the full definitions of the impact categories are in Appendix F.

## RATING THE BODY OF EVIDENCE

The strength of evidence (SOE) for each key question was assessed using the approach described in AHRQ's Methods Guide.^38^ We limited the Grading of Recommendations Assessment, Development and Evaluation (GRADE) ratings to those outcomes identified by the stakeholder and Technical Expert Panel as critical to decision making. In brief, this approach requires assessment of 4 domains: ROB, consistency, directness, and precision (Table 1).

Table 1 Strength of Evidence Required Domains

Domain | Rating | How Assessed
Quality (risk of bias) | Good Fair Poor | Assessed primarily through study design (randomized controlled trial vs observational study) and aggregate study quality
Consistency | Consistent Inconsistent Unknown/not applicable | Assessed primarily through whether effect sizes are generally on the same side of “no effect,” the overall range of effect sizes, and statistical measures of heterogeneity
Directness | Direct Indirect | Assessed by whether the evidence involves direct comparisons or indirect comparisons through use of surrogate outcomes or use of separate bodies of evidence
Precision | Precise Imprecise | Based primarily on the size of the confidence intervals of effect estimates, the optimal information size and considerations of whether the confidence interval crossed the clinical decision threshold for using a therapy

Additional domains were used when appropriate: coherence, dose-response association, impact of plausible residual confounders, strength of association (magnitude of effect), and publication bias. These domains were considered qualitatively, and a summary rating was assigned after discussion by 2 reviewers as high, moderate, or low SOE. In some cases, high, moderate, or low ratings were impossible or imprudent to make. In these situations, a grade of insufficient was assigned. This 4-level rating scale consists of the following definitions:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of an effect.

## PEER REVIEW

A draft version of this report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is provided in Appendix G.