# INTRODUCTION

Each year in the United States, more than 500,000 Americans, including 40,000 Veterans, are diagnosed with advanced cancer.^1^ Cancer is associated with various physical symptoms including pain and may affect quality of life (QOL), functionality, psychological health, and family systems.^2^ Palliative care services assist with managing physical symptoms and emotional, psychosocial, and spiritual distress of patients with serious illnesses such as cancer. Palliative care ideally begins at the time of diagnosis of a serious illness and continues until the end of life; it is appropriate at any stage of illness and can be provided along with curative treatment.^3^ Although primary care practitioners and oncologists have always incorporated palliative care into their treatment of patients, palliative care has become a specialty recognized by the Accreditation Council for Graduate Medical Education with board certification through the American Board of Internal Medicine.^4^

Many Veterans receive their treatment and supportive care services through the VHA, where palliative care services are often integrated with oncology care services during an inpatient hospital stay. All enrolled Veterans in the United States have access to palliative care during an acute VA hospital admission, which frequently addresses issues related to uncontrolled symptoms and goal-setting. Such integration of palliative care services with disease-directed care is now considered standard of care for patients with advanced cancer, guided by the recommendations of many influential cancer advocacy and membership organizations. Both the National Academy of Medicine and the American Board of Internal Medicine identify palliative care as integral to improving the quality of cancer care.^5,6^ Further, the American Society of Clinical Oncology has released both a provisional clinical opinion^7^ and a recent guideline^8^ calling for the regular integration of palliative care into standard oncology care. The Oncology Nursing Society has a similar position, recommending early integration of palliative care for patients with cancer.^9^ In addition, the American College of Surgeons' Commission on Cancer requires that cancer centers have access to palliative care services to be accredited by American College of Surgeons.^10^ Furthermore, the National Comprehensive Cancer Network^11^ has incorporated early palliative care integration into their evidence-based pathways for the routine care of patients with advanced cancers or high distress. To date, several clinical trials have demonstrated the value of this integrated approach to improve several cancer-related outcomes, including patient and caregiver satisfaction with care,^12^ health-related QOL,^13^ and potentially overall survival.^14^ Both a recent meta-analysis/systematic review^15^ and a Cochrane Collaboration review^16^ report consistent and significant improvements in patient QOL, symptoms, and caregiver mood across disease types and settings, demonstrating the applicability of these findings across multiple venues in which cancer patients receive care.

Increasing recognition of the value of specialty palliative care services has led to dramatic growth in the field as well as improvement in access to services. The clinical field of specialty palliative care has expanded by almost 150% across the United States in the last decade.^17^ Consultation services are available at 66% of all US hospitals, including 98% of National Cancer Institute (NCI)–designated cancer centers.^18^ This is a significant increase from an earlier report that demonstrated only 33% of NCI institutions having access. While palliative care has undergone increased acceptance and expansion, the nature of its integration with oncology services remains understudied and unclear. Palliative care can be delivered in inpatient as well as outpatient settings. Most palliative care services can be delivered by primary physicians or oncologists; however, specialty palliative care consultation teams that demonstrate significant variability in team composition, penetration of services among hospitalized patients, and outcomes related to financial savings to health systems are common.

Although integration of services is recommended for all patients with advanced cancers or high medical needs, uncertainties remain. For example, the majority of patients included in palliative care clinical trials have non–small cell lung cancer and, to a lesser extent, non-colorectal gastrointestinal cancers. Thus, the applicability of these trials' findings to other common cancer populations within VA, such as prostate and head and neck cancers, is not clear. Also, the most effective route to deliver palliative care interventions remains an open question. Some trials use a telephone-based approach, recognizing the need for distance-based education and follow-up for patients who live in rural communities and/or travel long distances for face-to-face care. Other trials use a more intensive, face-to-face approach, requiring a minimum number of visits within the trial. Further, the majority of participants in the palliative care intervention trials are white, raising questions about generalizability to nonwhite populations. Last, the ideal degree of integration has not been well described—particularly in complex health systems or among patients with multiple health care providers addressing serious illnesses in addition to cancer.

With the increase in availability of clinical palliative care services, organizations have tested and implemented varying degrees and types of integration with oncology care. These can be evaluated using common instruments, like the Integrated Practice Assessment Tool^19^ based on the health care integration framework by Heath et al.^20^ Adapted from this framework, levels of integration across palliative care and oncology have recently been proposed in the Collaborative Care Continuum framework by Kaufmann et al.^21^ In addition to levels of integration, leaders have described various methods of integration of services, including co-rounding models for hospitalized patients, embedded or colocated outpatient clinical services, and standalone clinics or services.^22,23^ Further, organizations have had positive experiences with integrated services limited to particular disease or conditions, types of therapy (eg, investigational agents or novel immunotherapy drugs), or by embedding palliative care experts into non-patient-facing case discussions such as multidisciplinary oncology team meetings (“tumor boards”).

In addition to other types of integration, much focus has been on the outpatient setting, which is where the majority of cancer care is delivered. For palliative care, the outpatient realm has been considered the “next frontier” of community-based palliative care services,^24,25^ and although growth is robust, many communities do not have access to non-hospital services.

Currently, all VA hospitals have inpatient access to palliative care programs for hospitalized Veterans, yet significant gaps in services remain in the outpatient setting. Though evidence supports some type of integration, which types and which populations to target have not yet been clearly elucidated to the degree that policymakers in VA have actionable information on which to move forward. Palliative care integration may present opportunity costs that when weighed against expansion of other types of supportive care services (eg, behavioral health, navigation, genetic counseling) may not take priority.

We aimed to perform a thoughtful and careful systematic review to provide actionable information to VA physicians, leaders, and policymakers regarding the potential benefits of types of palliative care integration among the diverse population of Veterans with cancer.